# Chapter 3 Future Research Needs for Health Care Modeling and Simulation Studies

## Introduction

Trade-offs between benefits and harms are common in most clinical contexts and should be weighed against each other in decisionmaking. Providers, patients, and policymakers are increasingly interested in complementing evidence of benefits and harms with information from modeling and simulation studies to explicitly answer pressing health care policy needs. Modeling of health care conditions and management options, ideally based on evidence from systematic reviews, can provide a single, comprehensive, explicit and interpretable analysis of uncertainty,^2^ values and resource utilization to guide decisionmaking and to support the prioritization of future clinical research activities.^3,4^ Modeling and simulation studies offer a coherent approach for integrating clinical research evidence and patient values to optimize choices and maximize expected utility for individual and for population health. However, as highlighted in Chapter 1, gaps remain regarding how best to conduct and report modeling and simulation studies.

The systematic review and panel discussion described in Chapter 1 underscored the need for further research on ways to improve upon the performance of and uses of modeling and simulation studies in the context of systematic reviews. Here, we describe the stakeholders' prioritization of future research needs topics to advance modeling and simulation.

## Methods

We conducted a systematic review of the published literature for evidence- and consensus-based guidance on the conduct of modeling and simulation studies. From the systematic review articles, we extracted suggestions for future research (both future research needs and research gaps) made by their authors. We then categorized the finding from the systematic review and convened an expert and stakeholder panel to discuss our findings and to prioritize future research needs in that context.

As described in Chapter 1, we formed a stakeholder panel that included experts in modeling and simulation, systematic review and evidence-based medicine, and epidemiology and biostatistics (See Appendix A for the list of stakeholders). Perspectives from six stakeholder categories were represented in the workshop^12^—patients and the public; providers of care; purchasers of care; payers; policy makers; and principal investigators, researchers and research funders. Several stakeholders represented more than one perspective. Policymakers, principal investigators, and providers were the most prevalent perspectives. Workshop participants included policy makers (from a range of national and international agencies and professional societies), AHRQ Evidence-based Practice Centers, guideline developers, CISNET (Cancer Intervention and Surveillance Modeling Network), modelers, epidemiologists, statisticians, professional societies, payers, and patient advocates. Appendix A lists the 28 stakeholders who participated in the panel. The panel met in-person or remotely at a workshop at AHRQ on 27 February 2013. The goals of the workshop were to review and expand the list of recommendations and research needs identified by the systematic review of methodology recommendations for modeling and simulation, and to prioritize research to improve the usefulness and credibility of models to inform decisionmaking.

Stakeholders were encouraged to comment on individual recommendations, identifying gaps, limitations and areas for expansion. They then discussed future research needs topics. The groups reviewed and discussed the list of future research needs gathered from our systematic review. The stakeholders were then asked to prioritize the list of future research needs derived from the systematic review. In addition, during the meeting, we solicited additional topics from participants, and following the meeting, the stakeholders prioritized these also. We engaged stakeholders in three groups, which met separately, as well as jointly. We refer to these three groups as “policymakers”, “principal investigators”, and “providers” to refer to the majority of the participants' perspective in each group. Stakeholders representing the perspectives of patients and the public, researchers and purchasers were dispersed in the three groups.

To direct discussions about future research needs and deliberations about their prioritization, we asked stakeholders to consider four dimensions of need—Importance, Desirability of new research, Feasibility, and Potential impact—described more fully in Table 4. Due to methodological restrictions to comply with Federal policies, we used multiple methods with our stakeholders to assess their priorities. At the meeting, stakeholders were provided with a form listing the future research needs derived from our systematic review and were asked to rank order each on a scale of 1 (“Not desirable”) to 10 (“Essential”), with an option for no opinion. After the meeting, stakeholders were sent the list of additional future research needs proposed by the stakeholders themselves and were asked for their ratings but, no specific method for rating was suggested. Most stakeholders who responded used a 1-10 scale but alternative methods used included categorizing into high, moderate, and low priority; 1 to 7 stars, and others. We therefore normalized all scales to a 10 point scale. Because of the different systems used to prioritize future research needs from the systematic review and the stakeholders, these two priority lists were kept separately. We selected the approximately five highest priority future research needs from each stage, using a natural breakpoint between higher and lower priority topics rather than a strict threshold of five topics.

Table 4 Dimensions of need (approach to prioritization)^*^

Dimension | Definition
Importance | - Represents a critical uncertainty for decision makers; - Advances credibility, transparency, and methodological rigor of modeling; - Represents important variation or controversy in modeling practice; - Represents high burden in time, effort, or resources to modelers
Desirability of New Research/Duplication | - Would not replicate ongoing or prior research, or established knowledge
Feasibility | - Ability to perform research
Potential Impact | - Potential for significant health or economic impact with clear implications for resolving important dilemmas in health and health care decisions or inequities or vulnerable population; - Frequency (high frequency implies greater potential impact, and vice versa)

* Based on Standardized Selection Criteria of the Agency for Healthcare Research and Quality's Effective Health Care Program.^110^

## Results

We reviewed 71 papers reporting recommendations for conducting modeling and simulation studies. The future research needs and research gaps presented in these papers are summarized in Table 5. Suggestions for future research were made in 38 of the 71 papers (54%).^5,10,15-17,19-22,24-27,29,30,32,36,37,39-41,43,44,48,50,53,54,57,59,60,62-64,66,67,70,72,75^ Initial discussion among stakeholders focused on the purpose of prioritizing future research needs with reasons including using models to guide grant funding and the distribution of research and funding across diseases, intervention types, and methods, and choosing appropriate topics for evidence review. Stakeholders felt that future research needs should span various model types. Aspects of model evaluation, including model validation and calibration, emerged as important targets for methodological research. Methodological advances in model evaluation were considered important for ensuring the validity and enhancing the credibility and acceptability of modeling results. Stakeholders presented multiple views across various future research needs. An example includes conflicting views expressed on the level of prioritization to place on using non-randomized trial data for assessing treatment effectiveness based on the existence of ongoing research on this topic.

Table 5 List of future research needs derived from the systematically reviewed articles

Future Research Needs | Prioritized Future Research Needs
| All stakeholders | Policymakers | Principal investigators | Providers
MODEL STRUCTURE
Incorporation of surrogate outcomes, often done naively, and in a 1-to-1 relationship between surrogate and clinical outcomes | X | | X
Methods for assessing transferability/generalizability of economic analyses
Develop and standardize techniques and processes for structuring complex models in the setting of HTA that are accessible to decision-makers
MODEL DATA
Use of non-randomized trial data for assessing treatment effectiveness, including bias assessment, bias modeling/corrections, and selection modeling | X | X | X | X
Multiparameter evidence synthesis, particularly for parameters not related to treatment effectiveness (NB: this includes indirect/network meta-analysis) | X | X | X | X
Parameterizing models for probabilistic sensitivity analysis, particularly when data for a parameter are sparse
Formalizing methods for interpreting non-probabilistic sensitivity analysis
Conceptualizing the search process for parameters other than treatment effectiveness; developing practical methods for searching, including standardized searches
Use of multi-level modeling of primary or secondary (aggregate) data, with a particular focus on using data from multi-center/multi-region studies
Assessing willingness to pay and developing conversion factors (for health outcomes)
MODEL CONSISTENCY
Determine optimal methods for model validation and calibration | X | X | X | X
Assessment of structural uncertainty | X | | X
Error research (research on methods for preventing and identifying errors in the modeling process) | | X
Methods for automated model checking (for structural errors as well as logical/numerical errors)
Methods for assessing indirect costs (e.g. for individuals outside the labor force)
RESULTS REPORTING AND INTERPRETATION
Implementation research on the application, use, and impact of modeling (are decisions/outcomes improved) | X | X | X | X
Work on developing flexible and comprehensive systems for evaluating completed economic analyses
Relationship between uncertainty, inference, and decision making? | | | | X
Determining threshold values for the incremental cost-effectiveness ratio

Future research needs prioritized by all stakeholders are in bold; those prioritized by only policymakers, principal investigators, or providers are in italics. Within categories, future research needs are listed in the order of prioritization by all stakeholders.

One group of stakeholders discussed the use of multilevel modeling of primary or secondary (aggregate) data, with a particular focus on using data from multicenter/multiregional studies as an important field for future research. This group also noted that the topics identified by the systematic review as targets for future research were somewhat “Euro-centric”, possibly reflecting the origin of a large number of the publications included in the review. The panel suggested that effort should be directed toward identifying additional research priorities with an emphasis on the United States health care system and its needs. Stakeholders uniformly emphasized the importance of performing research on “widening the audience for using models,” including research on how to communicate the results of modeling studies to different audiences. Discussions concluded with the identification of 30 additional future research needs to be included in prioritization exercise (Table 6).

Table 6 List of future research needs derived from stakeholders

Future Research Needs | Prioritized Future Research Needs
| All stakeholders | Policymakers | Principal investigators | Providers
MODEL STRUCTURE
Review of standards for best practice in fields outside medicine (e.g., engineering, operations research, environmental modeling, etc.) | X | | X
Research on using models in decision aids for shared decision-making | | | | X
Review of standards for best practices in the development of decision analysis and simulation models for patient-centered comparative effectiveness questions | | X
Research on the use of duplicate modeling (building independent models with common inputs) to explore structural uncertainty
Research on individualizing models – predictive value for individual patients | | | | X
How to build decision models to illustrate trade-offs in patient-centered outcomes
Developing multi-purpose/multi-disease models; research on “reusable models”, models that can be repurposed to be used for different decision problems that fit under the same model structure | | X
Identifying cases where relatively simple models are “good enough” for guiding decisions – for example, exploring cases where simple and more elaborate models agree or disagree, to identify patterns
Research on the choice of “appropriate” modeling approaches for different decisionmakers (considering policy vs. patient-level decisions and the trade-off between complexity and transparency) | | | | X
Review of standard for best practice within more specific topics (e.g., specific model types)
Computational complexity for some modeling is too high – and there is computer science or applied math approaches that could be explored | | | X
Research on multi-level modeling for populating models, with particular focus on using multi-level models to reflect variability in patterns of care
Framework for deducing the sufficient complexity of a model for a given question
When to model, what to model, how to model
Framework for pushing the use of conceptual modeling as the first step -- to help understand what's important and what is not
MODEL DATA
Modelers often “take data as they are” and plug them in; however we can break down the variability in the data into sampling error, bias, and heterogeneity; we need better understanding of the role of bias, and of how to handle it | X | | X | X
Emphasis on “not is it cost-effective” – but for whom is it cost-effective? In most cases this will involve the use of individual participant data | | | X
How to account for distributional justice/equity/utility tradeoffs (benefits for some are not accrued by others)
Research on appropriate measures of economic value (i.e., without focusing exclusively on willingness-to-pay)
What is a structural sensitivity analysis in one modeling approach is a parameter in another – understanding this duality is important as it is easier to handle the latter
Methods for multidimensional utility assessment (e.g., a joint utility for treatment and outcome sequences, a joint utility for combinations of morbidities versus combining separate utilities for single morbidities)
MODEL CONSISTENCY
Methods for accounting for heterogeneity including baseline risk and benefit, health status, and individual patient preferences | X | X
Development of methods to use simulation models to address questions on heterogeneity of treatment effect | | X
Assess quality and applicability of models
Performing cross model comparison and selecting a model
RESULTS REPORTING AND INTERPRETATION
Optimal methods of communication of models to end-users; additional education needs for communication; how models are used and communicated; Widening audience for using models – research on how to communicate results to different audiences | X | X | X | X
OTHER
Methods to engage and tailor methods and objectives to end users | | | | X
Methods for using value of information to choose among a broad range of alternative study designs for different interventions

Future research needs prioritized by all stakeholders are in bold; those prioritized by only policymakers, principal investigators, or providers are in italics. Within categories, future research needs are listed in the order of prioritization by all stakeholders.

Based on stakeholder feedback, the 10 future research needs that were considered high priority by the stakeholder panel as a whole are highlighted in Tables 5 and 6. The highest priority future research need about model structure is a review of the standards for best practices in fields outside of medicine, such as engineering and environmental modeling. The goal would be to ensure that modeling of medical topics uses the most up-to-date practices and to determine how medical models could be improved by using, testing and adapting methodological advances from outside health care. This future research need was of particular interest to principal investigators, those most likely to develop models and conduct simulations.

Another priority for future research pertained to incorporating surrogate outcomes in models, and to evaluating the assumptions invoked when using surrogate outcomes. Three future research needs were prioritized regarding where model data come from. Stakeholders wanted to better understand how nonrandomized trial data should be appropriately used, and if and how these data need to be assessed; how the bias inherent to many studies, regardless of design, ought to be handled; and what is the validity of, the indications for, and the best practices for conducting multiparameter synthesis.

Stakeholders prioritized three future research needs regarding model consistency. The highest priority among these is to determine which methods for model validation and calibration^a^ are most appropriate, most improve the validity and applicability of models, and which methods are most likely to be feasible for use. In addition, which methods should be used to examine the impact of alternative model structures and when this should be done.

Stakeholders also prioritized research into methods for accounting for heterogeneity within models, including baseline risk and benefit (or treatment heterogeneity), health status, and individual patient preferences. The stakeholders' logic, particularly policymakers, was that, in general, the most useful models are those that can be individualized for particular patients.

Implementation research on the application, use, and impact of modeling was identified as a future research priority for results reporting and. The goal of this research would be to determine how models can be framed and presented to maximize their value for real-world decisionmaking. Stakeholders also prioritized research into optimal methods to communicate models to end-users, including education of end-users, how models are presented, and how to fulfill the needs of different audiences.

It is worth noting that policymakers and providers, in particular, prioritized several different future research needs than the stakeholder panel as a whole, in line with their particular perspectives. Policymakers prioritized future research needs that address ensuring that models are accurate, patient-centered, re-usable, and address heterogeneity. Specifically, these included research on methods for preventing and identifying errors in the modeling process, best practices for developing models for patient-centered comparative effectiveness questions, developing multi-purpose and multi-disease models that can be repurposed, and methods to use simulation models to address questions on heterogeneity of treatment effects.

Providers' highest priority future research needs generally revolved around how to individualize models for patients and how to make them most useful in clinical practice. Specifically, these included research into the relationship between model results and decision making – on the relationship between uncertainty, inference, and decision making; how to use models in decision aids that are used for shared decision-making; how to individualize models and to provide predictive value for individual patients; and how to engage and tailor the model methods and objectives to end-users.

Principal investigators, in contrast, tended to prioritize future research needs regarding the mechanics of developing models. In addition, to the future research needs described above on assessment of structural uncertainty and best practice standards from outside of medicine, principal investigators also prioritized research into how to handle models for which the computational complexity is too high to develop and how to incorporate individual participant data into models to determine for which people are interventions cost-effective.

## Conclusions

Based on a systematic review of 71 publications providing recommendations for the conduct and reporting of modeling and simulation studies, we summarized a list of future research needs and presented these statements to a diverse stakeholder panel with expertise in modeling and simulation, systematic review and evidence-based medicine, and epidemiology and biostatistics. In addition, we solicited additional future research needs proposed by these stakeholders, who prioritized both lists of future research needs. The stakeholders prioritized future research needs with the goals of improving the methodology for the conduct of modeling, the validity of the models, and the communication of their findings. The future research needs were also prioritized primarily from the stakeholder perspectives it was believed most commonly directly use health care models, namely, policymakers, principal investigators and physicians. Other stakeholders (e.g., patients) were considered, but were thought to have a lesser direct impact from research into improving modeling methodology. The broad range of stakeholders included in this exercise highlighted a difference in priorities between policymakers and providers. Policymakers prioritized future research needs that address issues related to expanding the applicability of the models, in particular ensuring that models are accurate, patient-centered, re-usable, and address heterogeneity. Providers' highest priority future research needs generally revolved around interactions between providers and their patients, namely how to individualize models for patients and how to make them most useful in clinical practice.

Overall, the stakeholders prioritized a number of issues.

First, perhaps in recognition of the imminent “big data” revolution in health care, our stakeholders acknowledged the need to assess the appropriate use of non-randomized trial data for determining treatment effectiveness, including the potential for bias assessment, bias modeling/corrections, and selection modeling.^112^ For example, the Food and Drug Administration's Sentinel Initiative has led to its Mini-Sentinel Initiative and Observational Medical Outcomes Partnership which have now blossomed into the Reagan-Udall Foundation (RUF),^113^ an independent nonprofit public-private collaboration to generate post-marketing evidence from huge heterogeneous data sources of the use of FDA-regulated drugs, devices and procedures in the real-world so that the health care community can reliably identify harms and opportunities to improve patient care. Moreover, across health technology assessments agencies,^86,114^ recent reviews concerning the use of observational versus randomized trial data have identified conflicting recommendations with one agency preferring observational data.

Second, much work is needed to better understand how data from different sources—including randomized trials, other trials, database analyses, observational studies, epidemiological data—should be used and assessed in a given model and, possibly, adjusted for risk of bias. Current guidance on how to handle data from multiple sources relies on transparency, researcher judgment, and assessment of uncertainty.^5^ However, modelers would benefit from better evidence on how and whether to use, assess, and adjust for potentially biased data from multiple sources. The other related future research need considered multiparameter evidence synthesis, particularly for parameters not related to treatment effectiveness. Of note, multiparameter evidence synthesis includes indirect/network meta-analysis, an analysis tool for which there is a need for guidance about its use in models. Using Bayesian methods and Markov Chain Monte Carlo software, multiparameter evidence synthesis synthesizes a broad range of alternative evidence sources, but can also examine the consistency of the evidence provided by these multiple information sources.^115^ Stakeholders discussed the need for “chains of evidence” reasoning to piece together disparate pieces of evidence, such as evidence on intermediate and terminal outcomes, or evidence from different study designs. Having quantified the uncertainty in the underlying evidence base, such types of analyses can also be used to prioritize future research by examining the impact of reducing uncertainty. Although examples of multi-parameter evidence synthesis exist, interest has grown as demonstrated by a seven-part tutorial in Medical Decision Making.^116-122^

Third, regarding model consistency—specifically validation and verification methods—to improve model acceptability, models need to be validated and calibrated to ensure the credibility of modeling results.^11,123^ Multiple methods are available for both validation and calibration, but there is limited evidence comparing specific methods.^4^ Although CISNET colon cancer models have been systematically compared,^109^ studies are needed specifically to address which validation or calibration methods and approaches are most appropriate for alternative types of models for different diseases. Calibration methods vary in their time and resource requirements; thus, the most appropriate method may not be the “best” method in all circumstances. Lastly, increasing scientific journals have called for reproducible research as a foundation for scientific evidence.^11,124,125^ In modeling this would consist of cross model (between model) validation where independently produced models yield similar results (convergent validity).^126^

High profile journals such as Science,^127^ have called for shining light into computational science, i.e., black boxes. As articulated by Weinstein, “Decision makers will not readily accept results and cost-effectiveness. unless they can understand them intuitively and explain them to others in relatively simple terms.”^126^ Consistent with these trends, the stakeholder identified optimal methods of communication of models to end-users; additional education needs for communication; how models are used and communicated; widening audience for using models – research on how to communicate results to different audiences as a future research need.

Lastly, in an upcoming era of value-based payment for outcome, stakeholder prioritized the need to explore implementation research on the application, use, and impact of modeling (are decisions/outcomes improved). Models are commonly accepted in decision-making in such fields as environmental protection, weather prediction, and defense strategy, but less so in health care.^128^ Better use of up-to-date methods used in these and other fields could only improve medical models.

In conclusion, this systematic review and expert panel provides a comprehensive collation of methodological guidance developed through various methodological processes and identifies ways to improve upon and standardize the use of modeling and simulation in the context of systematic reviews. This review updates previous syntheses of evidence- and consensus-based guidance on the conduct of modeling and simulation studies and the stakeholder panel prioritizes future research topics needed to advance the current state-of-the-art in modeling and simulation.

a Validation and calibration are methods to test how the models comport with reality as measured by empirical data. As such they can provide information that enhances model credibility and acceptability as well as provide insights into the potential use of modeling decisions in practical settings.^111^