# Chapter 2 Review of Guidance from Health Technology Assessment Organizations

## Introduction

Health technology assessment (HTA) is a method of evidence synthesis that utilizes systematic review methodology to study the medical, social, ethical, and economic implications of development, diffusion, and use of health technology.^83^ HTA is evolving with the need for continued decisionmaker support when evaluating new technologies.^84^ Systematic review, utilizing meta-analytic techniques, provides best estimates of average effects of interventions and rates of outcomes (including benefits and harms). Given sufficient evidence, systematic review may also provide an indication about how effects of interventions may differ in different settings, among different people, and across variations of the interventions (e.g., different doses or diagnostic thresholds). However, systematic reviews alone often provide a poor basis to balance benefits and harms in different scenarios or for different patients, to balance benefits and the resources required to achieve them, or to incorporate individual values (preferences) into decisionmaking. Modeling can provide a comprehensive, transparent, and interpretable integration of empirical evidence on benefits and harms, preferences, and resource utilization, while accounting for all relevant sources of uncertainty. However, it is hard to determine when a model may be of sufficient value to justify the time and resources required to incorporate it alongside systematic reviews.^85^

The goal of this review is to identify and summarize guidance from international HTA organizations, agencies and institutes that assess new health technologies or economic evaluations regarding when and how to incorporate modeling alongside systematic reviews, specifically searching for descriptions regarding whether to integrate modeling as part of HTA, the timing of modeling in relation to the conduct of systematic review, modeling methodological recommendations, the potential budget impact of introducing the technology, and the effect of including modeling on the HTA project budget. We then categorized all available recommendations across HTA organizations to examine both differences and commonalities in guidance.

## Methods

Mathes et al. originally identified the HTA organizations through member lists of the International Network of Agencies for Health Technology Assessment (INAHTA), Health Technology Assessment International (HTAi) not-for-profit organizations, and the European Network for Health Technology Assessment (EUnetHTA).^86^ Building on this review we searched the web sites of 126 international agencies and institutes conducting HTA (HTA organizations) for guidance regarding when and how to apply modeling methodology. We used the list of “HTA organizations” in Mathes et al. without making further determination of whether each is truly an HTA organization. For our review, two researchers independently reviewed identified HTA organization web sites in January 2014 (Appendix C). Standardized screening procedures included use of web site navigation (e.g., hyperlinks utilizing key terms such as “publications”, “recommendation” and “methods”), web site search engines, and sitemaps to identify appropriate Web content and documents.

Relevant data were collected verbatim directly from web site text and linked documents available through the web site such as handbooks or guidelines on HTA methods. Non-English language web sites and documents were excluded from extraction. From each source, we extracted language from statements that could be read as recommendations, guidance, or standards regarding when and how to model including integration of modeling as part of HTA, modeling alongside systematic review of literature, timing of modeling with respect to the systematic review (i.e., concurrent or sequential), use of pre-existing versus established models, how to model, and budgetary considerations. The choice of guidance topics was determined prior to review of any of the relevant HTA organization documents. We did not search for methods pertaining to how HTA organizations determined their recommendations. Relevant language was extracted verbatim to standardized spreadsheets. Reviewers further categorized extracted language on when to model into 11 categories, as listed in Table 2. All extracted language and categorizations were reviewed by the entire project team for consensus.

Table 2 Questions for categorization of HTA guidance

Category | Question
Integration of modeling in HTA | Is modeling always a part of HTA?
Systematic review alongside modeling | Is modeling always informed by a systematic review?
Timing of modeling | Should modeling be performed concurrent with or after a systematic review once the parameters are set?
Use of pre-existing or established models | Should one use pre-existing or established models? Include the process for this decision (e.g., Is a systematic review of models conducted?; How is a model deemed adequate for use?)
Modeling recommendations | What are the methods for modeling?
How systematic review incorporated into the model | How should one incorporate the systematic review into the model?
Who conducts the model | Who should perform the modeling? What is the composition of the modeling team?
Inclusion of quality of life | Should the model include quality of life?
Inclusion of costs | Should the model include costs?
Budget analysis done | Should one conduct a budget analysis (e.g., a national budget impact analysis)?
Impact on project budget | Should one conduct an analysis of the impact of modeling on a project budget?

## Results

Of the 126 web sites, 21 (17%) provided relevant text regarding the application of modeling in the context of conducting a HTA.^87-107^ The remaining 106 web sites (84%) did not provide any guidance or were written in non-English languages and could not be translated (42 web sites, 33%). The 21 web sites with relevant, extractable data included HTA organizations from four continents including two HTA organizations in Asia (Taiwan and Thailand), three in Australia and New Zealand, 11 in Europe, and five in North America (3 U.S. and 2 Canada). A summary of available guidance on modeling across the 21 Web sites is presented in Table 3 and all recommendation made by the HTA organizations are tabulated in Appendix D. Details specific to each of the 11 subcategories are described below.

Table 3 Summary of available guidance on modeling from international HTA agencies

Web site | Integration of modeling in HTA | SR alongside modeling | Timing of modeling | Use of pre-existing or established models | Modeling recommendations | How SR incorporated into the model | Who conducts the model | Inclusion of quality of life | Inclusion of costs | Budget analysis done | Impact on project budget
Agency for Health Technology Assessment in Poland (AHTApol/Poland) | X | | | | X | | | X | X
Canadian Agency for Drugs and Technologies in Health (CADTH/Canada) | | | | | X | | | | X
Danish Centre for Health Technology Assessment (DACEHTA/Denmark) | X | | | | X | | | X | X
Health Information and Quality Authority (HIQA/Ireland) | X | X | X | | X | | | X | X | X
National Authority of Medicines and Health Products (INFARMED/Portugal) | | | X | | X
Institute for Quality and Efficiency in Health Care (IQWIG/Germany) | X | | | | | | | | X
Belgian Federal Health Care Knowledge Centre (KCE/Belgium) | X | | | | | | | X | X
MAS (Medical Advisory Secretariat, within the Ontario Ministry of Health and Long-Term Care Health Strategies Division/Canada) | | | | | X | | | | X
Medical Services Advisory Committee (MASC/Australia) | | | | | X | | | | X
National Institute for Clinical Excellence (NICE/UK) | X | X | X | X | X | X | | X | X | X
Pharmaceutical Benefits Advisor Committee (PBAC, Australia) | X | | | | X
Pharmaceutical Management Agency of New Zealand (PHARMAC/New Zealand) | X
AAZ (Agency for Quality and Accreditation in Health Care/Croatia) | | | | | X | | | | X
HITAP (Health Intervention and Technology Assessment Program/Thailand) | X | | | | X | | | | X | X
ICER (Institute for Clinical and Economic Review/US) | X | X | | X | X | X
LBI (Ludwig Boltzmann Institute for Health Technology Assessment/Austria) | X | | | | X
MHRA (Medicines and Healthcare Products Regulatory Agency/UK) | X | | | | X
NLM (National Library of Medicine/US) | X | | | | X | | | X | X
AHRQ (US Agency for Healthcare Research and Quality/US) | X | | X | X | X | X | X | X | X | | X
CAST (Centre for Applied Health Services Research and Technology Assessment, University of Southern Denmark) | X | X | X | | X | | | | X
CDE (Center for Drug Evaluation/Taiwan) | | X | | | | | | | | X

Abbreviation: SR, systematic review

Despite the relatively large number of international HTA organization web sites, only 17 percent (21 agencies) provided guidance regarding the application of modeling in the context of conducting an HTA. On average, each web site provided guidance on roughly 4 of the 11 subcategories regarding when and how to incorporate modeling. NICE and AHRQ provided the most guidance among the 21 web sites, addressing 9 out of 11 subcategories, followed by the Health Information and Quality Authority (HIQA/Ireland) providing guidance on 7 of the subcategories. All but one HTA organization (Pharmaceutical Management Agency of New Zealand) provided guidance on multiple subcategories. The most frequently reported guidance across HTA organization web sites addressed recommendations on how to model (17 agencies) and integration of modeling as part of HTA (15 agencies); only one HTA organization (AHRQ) provided guidance on who develops and implements the model.

### Integration of Modeling in HTA

Fifteen HTA organizations addressed incorporation of modeling in the context of conducting an HTA. Of these 15, six agencies required a model for their HTAs; three specifically as part of HTA development process and three as part of an economic evaluation process. Three other agencies recommended, but did not require, the incorporation of a model as part of HTA under certain conditions. For example, two recommended including models when conducting an economic evaluation. The remaining six agencies neither required nor recommended modeling as part of HTA. Rather they remained neutral on the topic while acknowledging that the technique has been used in prior agency reports.

### Systematic Review Alongside Modeling

Five HTA organizations addressed the conduct of systematic reviews to inform modeling. One mentioned modeling but did not specify whether it should always be conducted alongside systematic review or alongside HTA in general. Of the remaining four HTA organizations, only one web site stated that a model must always be prepared jointly with a systematic review when conducting HTA. The other three organizations did not always require a systematic review.

### Timing of Modeling

Five HTA organizations provided guidance on the timing of modeling in the context of conducting a HTA. Two recommended that the modeling be done concurrently with the systematic review while the other three recommended the modeling be done after the review once parameters have been estimated with one, however, acknowledging that it may not be feasible or timely to conduct the systematic review and model in sequence rather than in parallel.

### Use of Pre-existing or Established Models

Only three of the 15 HTA organizations addressed the use of pre-existing versus established models in the context of conducting a HTA. One did not favor the use of pre-existing or established models in HTA and recommended the development of a de novo model to accompany each systematic review. The remaining two HTA organizations acknowledged that it was acceptable to use pre-existing models under certain conditions; one required that the model be conducted by manufacturers and sponsors of the HTA and the other cautioned against using established models that are not flexible enough to represent the consequences of all interventions of interest.

### Modeling Recommendations

Seventeen of the 21 HTA organizations (81%) provided guidance on how to model. We divided these recommendations into four categories addressing whether or not the advice featured a statement on data, structure, validity and assumptions. Twelve of the 17 HTA organizations included a statement on model data, 14 addressed model structure, 6 addressed model validation, and 7 addressed model assumptions.

### How Systematic Reviews Were Incorporated Into the Modeling Process

Whether a model is prepared concurrently with or after the completion of a systematic reviews, the question remains how to incorporate the review results into the model. Three HTA organizations gave guidance on this issue with two stating that the model outcome estimates should be based on the systematic reviews. The remaining HTA organizations suggested that the systematic reviews be used to produce parameter estimates for use in sensitivity analyses.

### Who Conducts the Model

AHRQ was the only HTA organization addressing the question of who specifically should perform the modeling. They note that it is not always feasible for the systematic review team to also conduct a model since different expertise is needed. When separate teams are used, they should collaborate closely and should, ideally, reside in the same location.

### Inclusion of Quality of Life

All seven HTA organizations that comment on quality of life suggest that models should take into account differences in quality of life among health states. Four of the seven state that a model should always include quality of life. The other three state that quality of life should be incorporated when appropriate (e.g., when final utility results are needed or when there is adequate evidence about quality of life to include in the model).

### Inclusion of Costs

Fourteen HTA organizations provided advice on whether costs should be included in a model. Only four HTA organizations stated outright that costs should be incorporated into the model. Ten HTA organizations suggest using costs only for the conduct of a cost-effectiveness analysis.

### Budget Analysis Done

Four HTA organizations provided guidance on conducting a budget analysis and all recommended a budget impact analysis as part of HTA.

### Impact on Project Budget

AHRQ was the only HTA organization that addressed the impact of conducting a modeling project on the systematic review budget and suggested that “modeling efforts could easily consume 20 to 40 percent of the budget for a systematic review” if it were included as part of the review.^108^

## Conclusions

Mathes (2013),^86^ upon which our search was based, summarized recommendations on methods for the preparation of economic evaluation by international HTA organizations. We extended their review by summarizing the HTA organizations' recommendations within the framework laid out by Sculpher (2000),^8^ Philips (2004),^5^ and Kuntz (2013),^109^ as elaborated on by our systematic review of recommendations for modeling and simulation (Chapter 1). This structured framework, which allowed us to categorize recommendations into the 11 domains in Table 2, highlighted differences across HTA organizations with respect to the breadth and detail of guidance provided to modelers. The recommendations made by HTA organizations pertain to models conducted for the purposes of these organizations, primarily evaluation of new or costly technologies. The models used by the HTA organizations are often used by national agencies to determine coverage or clinical recommendations.

Despite the relatively large number of international HTA organization web site, only 17 percent (21 agencies) provided guidance regarding the application of modeling in the context of conducting an HTA. The majority of these HTA organizations are from Europe, Australia/New Zealand, and Canada. AHRQ provided the most guidance among the 21 web site followed by NICE and HIQA/Ireland. HTA organization mostly addressed how to model and how to integrate modeling into HTA.

The HTA organizations varied widely in what areas of modeling they provided guidance for and what specific recommendations they made. This is consistent with the heterogeneity across researchers and organizations in the recommendations on the conduct and reporting of modeling and simulation studies, described in Chapter 1. For example, although 17 HTA organizations provided guidance on how to model, guidance did not consistently address the same themes (i.e., data, structure, consistency) regarding how to model. Moreover, while 15 HTA organizations commented on the integration of modeling as part of HTA, not all HTA organizations required a model as part of HTA development. Finally, variation in the frequency of reporting across the 11 subcategories may reflect the relative importance of these aspects of modeling to specific agencies and/or countries.

A number of practical constraints may have limited our review of HTA organization web site. We relied on a previous review of HTA organization web site,^86^ which provided an apparently comprehensive listing of international HTA organization web site, but agencies not present on these lists may have provided additional modeling guidance. In addition, HTA organization guidance not provided on a web site were not included. We considered using Google Site Search (https://www.google.com/cse/sitesearch/create) to more comprehensively screen individual web site to identify modeling guidance however, the often large number of potentially relevant items identified by this search tool made using this methodology infeasible. In addition, about one-third of the web sites accessed (38 agencies) lacked an English language translation and could not be reviewed to identify additional relevant modeling guidance. Not all HTA organizations web site included “guidance,” per se, and it required a collective judgment call to categorize their guidance statements. Other readers may have categorized statements differently. We were also unable to obtain descriptions of methods used by the HTA organizations to determine their recommendations.

In summary, only a small number of HTA organizations (21 of 126) provide guidance on their web sites for incorporating modeling alongside systematic reviews. Most HTA organization that provided guidance made recommendations about whether to incorporate models into HTA, generally favoring including models. Most also provided recommendations on how to model, focusing primarily on model data and structure, with fewer recommendations on model assumptions or validation. Similarly, most addressed inclusion of costs in cost-effectiveness models. Few HTA organizations provided guidance related to other aspects of modeling in the context of HTA, including whether modeling should be conducted alongside systematic review, when modeling should be done related to the HTA, whether pre-existing models could be used, how systematic reviews should be incorporated into the modeling process, whether models should incorporate quality of life, whether a budget impact analysis should be done as part of the HTA, or who should conduct the modeling or the project budget impact of adding modeling to an HTA. Variability in recommendations probably reflects the heterogeneous needs addressed by HTA agencies operating in different jurisdictions. Harmonizing guidance across HTA agencies, and adopting a common set of best practices whenever possible, would allow for more efficient transport of modeling results (or specific model implementations) across agencies.