# Chapter 1 Systematic Review of Recommendations for the Conduct and Reporting of Health Care Modeling and Simulation Studies

## Introduction

Rigorous systematic reviews of the literature have become the preferred way to identify, appraise, and synthesize studies on the comparative effectiveness of competing health care interventions. However, users of such reviews―including patients, providers, and policymakers―may remain in doubt about which interventions to use because of persistent uncertainties, tradeoffs between benefits and harms, differences in preferences, or insufficient evidence.^1^ Even after a synthesis of best-available evidence, uncertainty may remain regarding the optimal choice among available interventions for important patient-relevant outcomes because studies may provide information mainly on surrogate outcomes, have short follow-up durations, or report inadequate subgroup data. Policy needs often require decision making under uncertainty and decision makers have become increasingly interested in complementing the results of systematic reviews of empirical evidence with information from modeling and simulation studies.

Modeling is especially useful when uncertainty exists about how specific evidence might be applied to a particular decisional context or a specific patient, or formulated into a recommendation. Modeling can provide a comprehensive and transparent integration of empirical evidence on benefits and harms, values (preferences), and resource utilization, while accounting for all relevant sources of uncertainty.^2^ Model results can be used to guide decision making and to support the prioritization and planning of future clinical research activities.^3,4^ Decision-making typically involves trade-offs in harms and benefits and thus may depend on individuals' values for a range of outcomes. Modeling offers a coherent approach for integrating clinical research evidence and patient values to optimize decision making. However, caution is warranted when models are based on insufficient, poor quality, or extrapolated evidence. Models whose structure and inputs are based on extensive background knowledge good quality evidence are likely to be more reliable.

Methods for the conduct of health care modeling and simulation have continued evolving to address the ever-increasing information needs of decision makers. The complexity and continued advances of the relevant methods have spurred the publication of recommendation statements on “best practices” for modeling and simulation. Two previous systematic reviews have assessed published recommendations and guidelines for decision analytic modeling for health technology assessment in an effort to identify methodological recommendations for decision-analytic modeling. Philips et al., in 2004, identified existing guidelines for best practices in health technology assessment and classified them into three domains—model structure, data, and consistency.^5^ Kuntz et al., in 2013, reviewed recommendations published through 2009 for developing, validating and using decision-analytic models in the context of systematic reviews.^1^ In addition to model structure, data, and consistency, they assessed a fourth domain pertaining to the communication of model results.

We sought to update and expand previous syntheses of evidence- and consensus-based guidance on health care modeling by performing a systematic review of published recommendation statements for modeling and simulation studies conducted on health care topics. We sought to address health care models broadly, regardless of whether they accompany systematic reviews or of their intended audience. To help contextualize and interpret the systematic review findings, we convened a meeting of diverse stakeholders, including modelers, users of models, and funders of research. Here we summarize the results of the systematic review and stakeholder input, to provide an up-to-date compendium of recommendations for best practices in health care modeling and simulation.

## Methods

The Tufts Evidence-based Practice Center, under contract with the Agency for Healthcare Research and Quality (AHRQ), conducted a systematic review of the published literature for evidence- and consensus-based guidance on the conduct of modeling and simulation studies. We convened a Clinical and Policy Advisory team (CaPA), and a Technical Expert Panel (TEP) to provide input in the design and conduct of the review (see Appendix A). The CaPA was formed to provide clinical and policymaking expertise from individuals who have used modeling input to inform decision-making. It included three members, with expertise and experience in applying decision analysis and simulation modeling for developing clinical guidelines, assessing public health risk management, and informing health care policy decisions. The TEP included four internationally-recognized experts in evidence synthesis and modeling and two policymakers and payers, who also have experience in modeling.

### Systematic Review

#### Search Strategy

We searched four electronic databases (MEDLINE, Cochrane Methodology Register, Health Technology Assessment Database, NHS Economic Evaluation Database) for articles presenting best practices in prioritization, conduct, and reporting of modeling and simulation studies through October 30, 2012. We based our search strategy on that used by Philips et al. and Kuntz et al. but substantially expanded the search terms to include keywords related to modeling methods and guideline statements.^1,5^ We confirmed that our search captured all articles reviewed by the two prior reviews, relevant articles from our personal bibliographies, and those suggested by CaPA, and TEP members. To make the size of the corpus that needed to be screened manageable (the search yielded 65,053 citations), we limited our screening to 37 journals identified based on the journals that published articles included by Philips et al. and Kuntz et al., supplemented with journals recommended by the CaPA and TEP as likely to publish guidance documents pertaining to decision analysis, simulation, economic analysis for health technology assessment, and health outcomes research. We also limited the search to articles published since 1990. The final search strategy, with the list of included journals, is presented in Appendix B.

#### Abstract Screening and Study Selection

Using the open-source abstract screening software Abstrackr (http://www.cebm.brown.edu/software),^6^ five reviewers independently screened abstracts in duplicate and resolved disagreements by group consensus. Eligible studies had to provide guidance on the elements of a good model, address the key elements that constitute a good modeling or simulation study, or provide explicit criteria against which to assess the quality or validity of models or simulations. Furthermore, we required that the guidance had to be either evidence-based (i.e., from a systematic review) or consensus-based (e.g., from discussion or collaboration of experts) and that articles provided a description of the process through which the authors arrived at their recommendations. Although this requirement excluded some older seminal articles,^7-10^ we found that their recommendations had been incorporated into more recent eligible articles. Examples of acceptable processes included systematic reviews, a Delphi consensus process, or presentation at a conference with active feedback from meeting attendees. We excluded articles that appeared to be based only on the opinions of the authors.

Eligible recommendation statements had to provide general guidance for modeling and simulation (e.g., guidance applicable across multiple disease topics such as comparative effectiveness of treatments, screening strategies, infection control, telemedicine) or for making formulary decisions at a national or regional level. Because of the potential for limited generalizability, we excluded guidance for modeling of specific disease types (e.g., chronic diseases such as cancer), local decision makers (e.g., hospital formularies), single modeling methodologies (e.g., Markov model, microsimulation model), or specific aspects of the modeling process (e.g., uncertainty propagation in models, reporting or dissemination of modeling guidance or results). Instead we focus on works that provide more broad guidance and make recommendations for a range of methods for and components of models and simulations. Such an example is the recent ISPOR-SMDM guidance, which covers all key specific aspects of modeling.^11^

We further excluded articles that provided recommendations for decision aids or for statistical analyses for estimating effect size, inference, or prediction; evaluated only costs; were related to clinical chemistry and laboratory medicine, occupational health, or vaccines; or dealt with multi-criteria decision analysis and analytic hierarchy process methods.

#### Data Extraction

We created a data extraction form based on the three-component framework originally proposed by Sculpher et al. in 2000^8^ and employed in a previous systematic review of methodological recommendations:^5^ model structure, model data, and model consistency. In addition, we added a component pertaining to the “communication of model results” as suggested by Kuntz et al. which we also found to be a useful addition to the original framework.^1^ Subcategories within the four thematic components were identified and operationally defined following Philips et al. (also see Figure 2 and Table 1 in this chapter).^5^ In each article, we identified specific recommendations as statements of policy or procedure that used modal verbs (e.g., “should,” “must”), that were placed in the context of other text as a suggestion for action, that were explicitly noted as a recommendation, or that were included in a checklist of items used to critically review a model. We then mapped each recommendation statement to the appropriate component—structure, data, consistency, presentation of results—and subcategories therein. For each publication, we also extracted the process for generating recommendations, the purpose of the recommendations or article, the target audience, and the intended scope of the recommendations.

Figure 2 Map of recommendation statements from the systematic literature review

Note: The figure presents a visual summary of the recommendation statements extracted from the systematic review. Columns represent the individual eligible papers (sorted left to right by number of recommendation subcategories). Rows represent recommendation topics. Thick black lines group subcategories belonging to the same component (from top to bottom: structure, data, consistency, and miscellaneous). Red crosses indicate recommendations based on systematic reviews, grey squares indicate expert panels, green circles indicate conferences or meeting, blue diamonds indicate “nonsystematic” reviews, and orange boxes indicate combinations of methods.

The figure presents a visual summary of the recommendation statements extracted from the systematic review. Columns represent the individual eligible papers (sorted left to right by number of recommendation subcategories). Rows represent recommendation topics. Thick black lines group subcategories belonging to the same domain (from top to bottom: structure, data, consistency, presentation of results and miscellaneous). Red boxes indicate recommendations based on systematic reviews, grey boxes indicate expert panels, green boxes indicate conferences or meeting, blue boxes indicate “nonsystematic” reviews, and orange boxes indicate combinations of methods.

Table 1 Recommendation types, by process of generation

| Reporting Items, by category | All documents N=71 | SR N=14 | Expert panel N=28 | Conf/Mtg N=7 | Non-SR N=14 | Combo N=8
Structure | objective | 40 (56) | 7 (10) | 15 (21) | 4 (6) | 9 (13) | 5 (7)
Structure | modeling approach | 32 (45) | 5 (7) | 15 (21) | 4 (6) | 4 (6) | 4 (6)
Structure | scope & perspective | 52 (73) | 9 (13) | 22 (31) | 6 (8) | 10 (14) | 5 (7)
Structure | rationale for structure | 33 (46) | 5 (7) | 14 (20) | 3 (4) | 8 (11) | 3 (4)
Structure | structural assumptions | 17 (24) | 5 (7) | 7 (10) | 2 (3) | 1 (1) | 2 (3)
Structure | comparators | 46 (65) | 8 (11) | 22 (31) | 3 (4) | 8 (11) | 5 (7)
Structure | model type | 12 (17) | 4 (6) | 3 (4) | 0 (0) | 2 (3) | 3 (4)
Structure | time horizon | 36 (51) | 7 (10) | 17 (24) | 3 (4) | 5 (7) | 4 (6)
Structure | disease pathways | 6 (8) | 2 (3) | 2 (3) | 0 (0) | 0 (0) | 2 (3)
Structure | cycle length | 5 (7) | 2 (3) | 2 (3) | 0 (0) | 0 (0) | 1 (1)
Structure | parsimony | 12 (17) | 2 (3) | 5 (7) | 2 (3) | 1 (1) | 2 (3)
Data | data identification | 40 (56) | 8 (11) | 17 (24) | 3 (4) | 7 (10) | 5 (7)
Data | premodel data analysis | 15 (21) | 5 (7) | 6 (8) | 0 (0) | 2 (3) | 2 (3)
Data | baseline data | 12 (17) | 4 (6) | 4 (6) | 0 (0) | 1 (1) | 3 (4)
Data | treatment effects | 25 (35) | 4 (6) | 11 (15) | 2 (3) | 3 (4) | 5 (7)
Data | costs | 49 (69) | 9 (13) | 20 (28) | 4 (6) | 10 (14) | 6 (8)
Data | utilities | 28 (39) | 3 (4) | 17 (24) | 2 (3) | 2 (3) | 4 (6)
Data | data incorporation | 30 (42) | 8 (11) | 10 (14) | 3 (4) | 6 (8) | 3 (4)
Data | assessment of uncertainty | 13 (18) | 5 (7) | 2 (3) | 1 (1) | 1 (1) | 4 (6)
Data | sensitivity analysis | 40 (56) | 6 (8) | 19 (27) | 4 (6) | 7 (10) | 4 (6)
Data | methodological uncertainty | 6 (8) | 2 (3) | 2 (3) | 1 (1) | 0 (0) | 1 (1)
Data | structural uncertainty | 8 (11) | 1 (1) | 4 (6) | 2 (3) | 0 (0) | 1 (1)
Data | heterogeneity and uncertainty | 18 (25) | 7 (10) | 6 (8) | 1 (1) | 3 (4) | 1 (1)
Data | parameter uncertainty | 29 (41) | 7 (10) | 13 (18) | 2 (3) | 2 (3) | 5 (7)
Consistency | internal validity | 14 (20) | 5 (7) | 3 (4) | 1 (1) | 2 (3) | 3 (4)
Consistency | external validity | 19 (27) | 2 (3) | 10 (14) | 3 (4) | 2 (3) | 2 (3)
Consistency | predictive validity | 4 (6) | 1 (1) | 3 (4) | 0 (0) | 0 (0) | 0 (0)
Consistency | differences across models | 7 (10) | 1 (1) | 3 (4) | 0 (0) | 1 (1) | 2 (3)
Other | incremental analysis | 24 (34) | 2 (3) | 12 (17) | 2 (3) | 5 (7) | 3 (4)
Other | other, including reporting | 52 (73) | 9 (13) | 24 (34) | 5 (7) | 11 (15) | 3 (4)

All results are expressed as number of papers (percentage of papers, out of 71).

Combo = combination of methods, Conf/Mtg = conference or meeting, SR = systematic review.

### Stakeholder Meeting

We invited workshop participants who would represent expertise in modeling and simulation, systematic review and evidence-based medicine, epidemiology, and biostatistics, and perspectives from six stakeholder groups: patient representatives, providers of care, purchasers of care, payers, policy makers (including research funders and professional societies), and principal investigators^12^ In total 43 individuals were invited to participate and 28 attended the 1-day meeting in-person or remotely.

The goals of the workshop were to review and expand the list of recommendations and research needs identified by the systematic review of methodological recommendations for modeling and simulation and to develop a list of priority research areas aiming to improve the usefulness and credibility of models used to inform decision making. Results regarding future research needs will be reported separately.

One of the authors (JBW) began the meeting with a presentation about modeling to ensure common background knowledge and vocabulary and to set the ground rules for the ensuing discussions. We then presented the categories and topics of recommendation statements identified by the systematic review, followed by a group discussion involving all participants. After assignment into three smaller groups (each comprising 7 to 12 participants), stakeholders reviewed and discussed the modeling recommendations in-depth over two breakout sessions. One investigator facilitated each session (JBW, EMB, and IJD) and a second investigator kept detailed notes (DM, TAT, or JAC) to supplement the tape-recording of the discussions. Facilitators reviewed the goals for each session and used a list of topics to guide the unstructured discussions. Stakeholders were encouraged to comment on available recommendations and identified gaps, limitations and areas for expansion within each component of interest. Key points from each of the small group discussions were presented to the whole group for further discussion. Following the meeting, we circulated summaries from all discussions to participants and solicited additional comments via email.

## Results

### Systematic Review of Published Recommendations

The search (Appendix B) yielded 6825 citations (Figure 1); the TEP and CaPA suggested 20 additional articles. We reviewed 358 articles in full text, of which 71 met our eligibility criteria and reported recommendations for conducting modeling and simulation studies. ^5,7,10,13-80^ Of these, 28 provided recommendations based on expert panel deliberations, 14 on systematic literature reviews, 14 on nonsystematic literature reviews, 7 on conference discussions, and 8 on a combination of these methods.

Figure 1 Flow diagram for papers presenting recommendations for modeling and simulation

Beginning with 6825 abstracts, 6467 were excluded and 358 full-text articles were considered for inclusion. Then, TEP and CaPA suggested 20 additional articles, of the total, 307 articles were excluded and finally 71 full text articles were included.

The complete list of extracted information is available electronically on the Systematic Review Data Repository (project title: Recommendations for modeling and simulation studies).

Figure 2 presents a summary of the recommendation types extracted from each article, along with information on the process used to generate the recommendations. When examining a single row of the matrix, a preponderance of filled cells indicates that most articles have provided recommendations addressing a specific area. For example, defining the scope and perspective of the analysis is the most common area of recommendations across the articles we reviewed. When examining a single column of the matrix, a preponderance of filled cells indicates that a given paper has provided recommendations addressing many different areas. For example, the paper by Philips et al. (2004) addressed all but two of the areas we examined.^5^

The majority of articles (64/71; 90%) provided one or more recommendations regarding model structure, including modeling objectives (40/71; 56%); model scope and perspective (52/71; 73%), and choice and justification of comparators used in modeling (46/71; 65%). Nearly all (68/71; 96%) made recommendations about obtaining appropriate data to populate models (main and sensitivity analyses), including obtaining cost data (49/71; 69%), methods for data identification and synthesis (40/71; 56%), and the conduct of sensitivity analyses (40/71; 56%). A minority of articles provided recommendations regarding the assessment of model consistency (27/71; 38%). Recommendations about model validity mainly pertained to internal (14/71; 20%) and external validity (19/71; 27%), with only a small number addressing the predictive validity of models (4/71; 6%). Table 1 gives the count of recommendation types for all 71 articles and stratified by process used to generate the recommendations. Overall, no clear pattern of association between process and specific recommendation types was apparent.

### Stakeholder Panel Discussions

The stakeholder group, together with the CaPA, TEP, and the investigators, as well as representatives from AHRQ, met for a day-long series of sessions on 27 February 2013 at AHRQ headquarters (Rockville, MD), to comment and deliberate on the findings of the systematic review (see Appendix A). After reviewing the list of recommendations, stakeholders uniformly agreed on the need to increase transparency of various modeling processes. Initial discussions centered on clarifying individual recommendations and, occasionally, their classification into the four components (structure-data-consistency-communication of results). Stakeholders highlighted the importance of recommendations that apply broadly, across multiple types of models. Questions were raised on the appropriateness of using the Philips et al. report as a framework and whether individual recommendations should be bundled/re-bundled or stand alone.^5^ While recognizing that the classification of recommendations into the four components involved judgments, we believe that it will be helpful to modelers seeking to identify guidance related to a specific aspect of their work.

In small group discussions, stakeholders questioned the value of yet another “checklist of recommendations”. Many felt it would be more helpful to identify “best practices” or “principles” on how to integrate modeling and the systematic review processes. They stressed the importance of understanding the needs and perspectives of the different stakeholders who might use model results, with particular consideration of patient preferences. Participants strongly indicated that the presentation and contextualization of modeling results to different stakeholders (e.g., policy-makers) remains an understudied area that is as important as developing methodological guidance for the conduct of modeling and simulation studies.

## Conclusions

This systematic review updates and organizes recommendations for health care modeling and simulation studies into four domains. It classifies recommendations by domain and by the methods used to develop them. A synthesis of these recommendations, together with additional sources of information on modeling and simulation, has been attempted in the accompanying report titled Guidance for the Conduct and Reporting of Modeling and Simulation Studies in the Context of Health Technology Assessment (http://effectivehealthcare.ahrq.gov/index.cfm/search-for-guides-reviews-and-reports/?pageaction=displayproduct&productid=2315).

Over 90 percent of recommendation documents provided one or more recommendations pertaining to model structure and data appropriateness, but only a minority provided recommendations regarding model validity. One might conjecture that the recommendation topics that were most frequently addressed in the papers we reviewed were either the most important (as perceived by those making the recommendations) or the easiest to address (on the basis of available theoretical or empirical evidence). Given the critical importance of assessing model validity,^11^ the absence of recommendations on methods for model validation more likely reflects uncertainty about the most appropriate methodological approaches. We review issues related to model validation and calibration in Chapter 4 of this report.

We discussed the findings of the systematic review with a diverse stakeholder panel that included patient representatives, providers of care, purchasers of care, payers, policy makers (from a range of national and international agencies and professional societies), and principal investigators, many with expertise in modeling and simulation, systematic review methods, epidemiology, and biostatistics (See Appendix A for the list of stakeholders). These discussions highlighted the importance of transparency in modeling methods in decision analysis applications and the need to identify best practices, rather than use “cookbook” checklists. When applied to complex methodological decisions (such as the design and conduct of modeling and simulation studies) checklists tend to promote mechanistic approaches that do not adequately address the practical challenges faced by modelers. Alternatively, determining the theoretical considerations relevant to each research problem and working from “first principles” may result in more fundamentally sound models. Nonetheless, checklists can increase consistency in the reporting of the methods and findings of modeling and simulation studies, and in the peer review of modeling research.^31,81^

Our work has limitations that need to be considered when interpreting our results. The majority of the recommendation statements we reviewed were derived from the medical literature, leading to a preponderance of statements regarding economic analyses (using modeling and simulation methods). Nonetheless, outside of cost-related considerations, many of the recommended methodological principles apply across multiple model types, as presented in our annotated bibliography of recommendations. More generally, systematic reviews of methodological topics are usually less likely to be comprehensive than reviews of empirical research studies (e.g., clinical trials) because of the unavailability of standardized indexing terms and the large number of sources that need to be searched. Further, we only classify guideline statements into four broad domains (components) and sub-components, without attempting to reconcile conflicting statements or to provide a synthesis across statements. Such a synthesis would be an appropriate task for a recommendation-making panel, such as the group updating the recommendations of the Second Panel on Cost Effectiveness in Health and Medicine (personal communication, Prof. Peter Neumann).^82^

In conclusion, this systematic review and stakeholder meeting summary provides a comprehensive compendium of guidance documents for modeling and simulation studies, annotated with information on the domains covered by each document, and the methods used to arrive at specific recommendations. Our annotated bibliography will be useful to modelers and others looking for sources of evidence- or consensus-based guidance. We have also incorporated this review of the existing guidance into a separate document: Guidance for the Conduct and Reporting of Modeling and Simulation Studies in the Context of Health Technology Assessment (http://effectivehealthcare.ahrq.gov/index.cfm/search-for-guides-reviews-and-reports/?pageaction=displayproduct&productid=2315).