# Appendix C Health Technology Assessment Organizations

Health Technology Assessment (HTA) Organization | Web site
AAZ (Agency for Quality and Accreditation in Health Care, Croatia) | http://www.aaz.hr/
AETMIS (Agence d´Évaluation des Technologies et des Modes d´Intervention en Santé) | http://www.aetmis.gouv.qc.ca/site/accueil.phtml
AETS ICS III (Agencia de Evaluación de Tecnologias Sanitarias) | http://www.isciii.es/htdocs/en/investigacion/Agencia_quees.jsp
AETSA (Andalusian Agency for Health Technology Assessment) | http://www.juntadeandalucia.es/salud/servicios/aetsa/
Age.Na:s (Agenzia Nazionale per I Servizi Sanitari Regionali) | http://www.agenas.it/
Agency for Health Technology Assessment in Poland (AHTApol/Poland) | http://www.aotm.gov.pl/index.php?id=397
AHRQ (US Agency for Healthcare Research and Quality) | http://www.effectivehealthcare.ahrq.gov/tools-and-resources/researcher-resources/
AHTA (Adelaide Health Technology Assessment) | http://www.adelaide.edu.au/ahta/
AIFA (Agenzia Italiana Del Farmaco) | http://www.agenziafarmaco.it/en
ARESS (Agenzia Regionale per i Servizi Sanitari) | http://www.aress.piemonte.it/Links.aspx
ARSENÁL (Veneto's Research Centre for e-Health Innovation) | http://www.consorzioarsenal.it/en/web/guest/home
ASERNIP-S (Australian Safety and Efficacy Register of New Interventional Procedures –Surgical) | http://www.surgeons.org/racs/research-and-audit/asernip-s/asernip-s-publications
ASSR (Regione Emilia Romagna, Agenzia Sanitaria e Sociale Regione Emilia Romagna) | http://asr.regione.emilia-romagna.it/
AVALIA-T (Galician Agency for Health Technology Assessment) | http://www.sergas.es/MostrarContidos_Portais.aspx?IdPaxina=60538
BAG (Bundesamt für Gesundheit) / FOPH (Federal Office of Public Health) | http://www.bag.admin.ch/index.html?lang=de
BCBS (Blue Cross BlueShield Association) | http://www.bcbs.com/
Belgian Federal Health Care Knowledge Centre (KCE/Belgium) | https://kce.fgov.be/
BS-CA (Blue Shield of California Foundation) | http://www.blueshieldcafoundation.org/
CAHIAQ (Catalan Agency for Health Information, Assessment and Quality) (formerly CAHTA) | http://www.gencat.cat/salut/depsan/units/aatrm/html/en/dir394/index.html
Canadian Agency for Drugs and Technologies in Health (CADTH/Canada) | http://www.cadth.ca/en
CAST (Centre for Applied Health Services Research and Technology Assessment, University of Southern Denmark) | http://www.sdu.dk/Om_SDU/Institutter_centre/CAST?sc_lang=en
CDE (Center for Drug Evaluation) | http://www.cde.org.tw/English/Pages/e-default.aspx
CEDIT (Comité d'Evaluation et de Diffusion des Innovations Technologiques) | http://cedit.aphp.fr/-Pays-.html?rubrique&lang=en&dir=ltr
CEM (Cellule d'expertise médicale) | http://www.ms.public.lu/fr/actualites/2011/04/02-offre-d-emploi/index.html
CENETEC (Centro Nacional de Excelencia Tecnológica en Salud) | http://www.cenetec.salud.gob.mx/
CMeRC - HTA Unit | Not available
CMTP (Center for Medical Technology Policy) | http://www.cmtpnet.org/
CNHTA (Committee for New Health Technology Assessment) | http://www.cha.ac.kr/
CRD (Centre for Reviews and Dissemination) | http://www.york.ac.uk/inst/crd/
CVZ (College voor Zorgverzekeringen, Dutch health care insurance board) | http://www.cvz.nl/en/home
DAHTA@DIMDI (Deutsche Agentur für Health Technology Assessment - Bewertung gesundheitsrelevanter Verfahren – Deutsches Institut für medizinische Dokumentation und Information) | http://www.dimdi.de/static/de/index.html
Danish Centre for Health Technology Assessment (DACEHTA/Denmark) | http://www.sst.dk/English/DACEHTA.aspx
DECIT-CGATS - Secretaria de Ciência, Tecnologia e Insumos Estratégicos, Departamento de Ciência e Tecnologia | http://portal.saude.gov.br/portal/saude/profissional/visualizar_texto.cfm?idtxt=25516
DSI (Danish Institute for Health Services Research) | http://dsi.dk/english/
EMKI (Institute for Healthcare Quality Improvement and Hospital Engineering) | http://www.emki.hu/site/index.php
ESKI (National Institute for Strategic Health Research) | http://www.eski.hu/index_en.php
ETESA (Department of Quality and Patient Safety of the Ministry Health of Chile) | http://www.redsalud.gov.cl/portal/url/page/minsalcl/g_home/home.html
FEGAS (School of Health Administration) | http://www.sergas.es/MostrarContidos_Portais.aspx?IdPaxina=50200
FIMEA (Finnish Medicines Agency) | http://www.fimea.fi/frontpage
FinOHTA (Finnish Office for Health Technology Assessment) | http://finohta.stakes.fi/EN/index.htm
G-BA (Gemeinsamer Bundesausschuss) | http://www.g-ba.de/
GÖG/BIQG (Gesundheit Österreich GmbH) | http://www.goeg.at/
GR (Gezondheidsraad) | http://www.gezondheidsraad.nl/
GYEMSZI (National Institute for Quality- and Organizational Development in Healthcare and Medicines) | http://www.ogyi.hu/gyemszi/
HA (Hospital authority Hong Kong) | http://www.ha.org.hk/visitor/ha_index.asp
HAS (Haute Autorité de Santé) | http://www.has-sante.fr/portail/jcms/c_5443/english?cid=c_5443
Health Information and Quality Authority (HIQA/Ireland) | http://www.hiqa.ie/
HIS (Health Care Improvement Scotland) | http://www.healthcareimprovementscotland.org/home.aspx
HITAP (Health Intervention and Technology Assessment Program) | http://www.hitap.net/en/splash
HSAC (Health Services Assessment Collaboration) | http://www.healthsac.net/
HTA-HSR/DHTA (HTA & Health Services Research) | http://www.centerforfolkesundhed.dk/om+centret/in+english
HVB, Hauptverband der Österreichischen Sozialversicherungsträger | http://www.sozialversicherung.at/portal27/portal/esvportal/start/startWindow?action=2&p_menuid=2&p_tabid=1
ICER (Institute for Clinical and Economic Review) | http://www.icer-review.org/
ICTAHC (Israel Center for Technology Assessment in Health Care) | http://www.health.gov.il/subjects/
IECS (Institute for Clinical Effectiveness and Health Policy) | http://www.iecs.org.ar/
IER (Institute for Economic Research) | http://www.ier.si/index.php
IHE (Institute of Health Economics) | http://www.ihe.ca/
INESSS - Institut national d'excellence en santé et en services | http://www.inesss.qc.ca/index.php?id=50&L=1
Institute for Quality and Efficiency in Health Care (IQWIG/Germany) | https://www.iqwig.de/en/home.2724.html
IPP (Institut für Public Health und Pflegeforschung, Universität Bremen) | http://www.ipp.uni-bremen.de/index.php
IRF (Institute for Rational Pharmacotherapy) | http://www.irf.dk/en/home.htm
JAZMP (Agency for Medicinal Products and Medical Devices) | http://www.jazmp.si/index.php?id=105
Kaiser Permanente | https://www.kaiserpermanente.org/
KDTD (Turkish Evidence-Based Medicine Association) | http://www.kanitadayalitip.org/index_eng.html
Kela (The Social Insurance Institution of Finland) | http://www.kela.fi/in/internet/english.nsf
Laziosanità (Agenzia di Sanità Pubblica, Regione Lazio) | http://www.regione.lazio.it/web2/contents/sanita.php
LBI (Ludwig Boltzmann Institute for Health Technology Assessment) | http://hta.lbg.ac.at/page/homepage
MaHTAS (Health Technology Assessment Section, Ministry of Health Malaysia) | http://www.moh.gov.my/health_assesments
MAS (Medical Advisory Secretariat, within the Ontario Ministry of Health and Long-Term Care Health Strategies Division) | http://www.health.gov.on.ca/english/providers/program/mas/tech/tech_mn.html
Medical Services Advisory Committee (MASC/Australia) | http://www.msac.gov.au/
MHRA (Medicines and Healthcare Products Regulatory Agency) | http://www.mhra.gov.uk/index.htm/
MOH Indonesia (Ministry of Health – Republic of Indonesia) | http://www.depkes.go.id/en/
MOH RS (Ministry of Health – Serbia) | http://www.zdravlje.gov.rs/index.php?
MOH Singapore (Ministry of Health – Singapore) | http://www.moh.gov.sg/content/moh_web/home.html
MOH Spain (Ministry of Health – Spain) | http://www.msc.es/
MOH-CZ (Ministry of Health - Czech Republic) | http://www.mzcr.cz/En/
MTAA (Medical Technologies Association of Australia) | http://www.mtaa.org.au/pages/index.asp
MTU-SFOPH (Medical Technology Unit - Swiss Federal Office of Public Health) | http://www.bag.admin.ch/
National Authority of Medicines and Health Products (INFARMED/Portugal) | http://www.infarmed.pt/portal/page/portal/INFARMED/ENGLISH
National Institute for Clinical Excellence (NICE/UK) | http://www.nice.org.uk/
NBoH (National Board of Health) | http://www.sst.dk/
NCPE (National Centre for Pharmacoeconomics, St. James's Hospital) | http://www.stjames.ie/Departments/DepartmentsA-Z/N/NationalCentreforPharmacoeconomics/DepartmentOverview/
NCPHP (National Centre of Public Health Protection) | http://ncphp.government.bg/
NECA - National Evidence-based healthcare Collaboration Agency | http://www.neca.re.kr/eng/
NETSCC, HTA - NIHR (Coordinating Centre for Health Technology Assessment) | http://www.hta.ac.uk/
Newcastle University | http://www.ncl.ac.uk/
NHG (National Healthcare Group) | http://www.nhg.com.sg/
NHMRC | http://www.nhmrc.gov.au/
NHS QIS (Quality Improvement Scotland) | http://www.nhshealthquality.org/nhsqis/CCC_FirstPage.jsp
NHSC (National Horizon Scanning Centre) | http://www.haps.bham.ac.uk/publichealth/horizon/
NIPH-RS (National Institute of Public Health of the Republic of Slovenia) | http://www.ivz.si/
NLM (National Library of Medicine) | http://www.nlm.nih.gov/
NOKC (Norwegian Knowledge Centre for the Health Services) | http://www.kunnskapssenteret.no/Home?language=english
NSPH (National School of Public Health) | http://www.nsph.gr/default.aspx?page=home
OSTEBA (Basque Office for Health Technology Assessment) | http://www.osanet.euskadi.net/r85-osteba/es/contenidos/informacion/osteba/es_osteba/osteba.html
PATH (Programs for Assessment of Technology in Health Research Institute) | http://www.path-hta.ca/Home.aspx
PenTAG (Peninsula Technology Assessment Group) | Not available
Pharmaceutical Benefits Advisor Committee (PBAC, Australia) | http://www.health.gov.au/internet/main/publishing.nsf/Content/pbac-outcomes-info
Pharmaceutical Management Agency of New Zealand (PHARMAC/New Zealand) | http://www.pharmac.govt.nz/
QPACT (Queensland Policy and Advisory Committee for New Technology) | http://www.health.qld.gov.au/newtech/html/QPACT.asp
Regione Veneto (Regione Veneto, Direzione Piani e Programmi Socio Sanitari) | http://www.regione.veneto.it/channels
Reglom-DGSAN (Regione Lombardia Direzione Generale Sanita) | http://www.sanita.regione.lombardia.it/cs/Satellite?c=Page&childpagename=DG_Sanita/DGHomeLayout&cid=1213277054618&pagename=DG_SANWrapper
RIZIV (Rijksinstituut voor ziekte- en invaliditeitsverzekering) | http://www.riziv.fgov.be/presentation/nl/index.htm
santésuisse (Branchenverband der schweizerischen Krankenversicherer) | http://www.santesuisse.ch/de/dyn_output.html?content.vname=portal
SBU (Swedish Council on Technology Assessment in Health Care) | http://www.sbu.se/en/
ScHARR (Technology Assessment Group, University of Sheffield) | http://www.shef.ac.uk/scharr/sections/heds/collaborations/tag
SIDC (State Institute for Drug Control) | http://www.sukl.sk/en/about-us
SingHealth (Singapore Health Service) | http://www.singhealth.com.sg/Pages/Home.aspx
SLOVATHA (Slovak Agency for Health Technology Assessment)
SNHTA (Swiss Network for HTA) | http://www.snhta.ch/
SNSPMS (National School of Public Health, Management d Professional Development) | http://www.snspms.ro/
SPC on Standardization and HTA | Not available
SSD/MSOC (Ministry for Social Policy, Strategy and Sustainability Division) | Not available
Sundhed.dk (Centre for Public Health, Central Denmark Region, department HTA & Health Services Research) | http://www.cfk.rm.dk/om+os/in+english/health+technology+assessment+and+health+services+research
TLV (Dental and Pharmaceutical Benefits Agency) | http://www.tlv.se/in-english-old/in-english/
UCEETS - The National Coordination Unit of Health Technology Assessment and Implementation | http://www.msal.gov.ar/pngcam/
UETS (Unidad de Evaluación de Tecnologías Sanitarias) | http://www.madrid.org/cs/Satellite?cid=1142494649964&language=es&pagename=PortalSalud/Page/PTSA_pintarContenidoFinal&vest=1142494649964
UFI-SALUD (Unidad de Financiamiento Internacional de Salud) | http://www.ufisalud.gov.ar/
UMIT (Private Universität für Gesundheitswissenschaften, Medizinische Informatik und Technik) | http://www.umit.at/page.cfm?vpath=index
University Hospital A. Gemelli | http://www.rm.unicatt.it/
UTA (University of Tartu , Department of Public Health) | http://www.ut.ee/en
UVT (HTA Unit in A. Gemelli Teaching Hospital) | http://www.policlinicogemelli.it/area/?s=206
VASPVT (State Health Care Accreditation Agency under the Ministry of Health of the Republic of Lithuania) | http://www.vaspvt.gov.lt/index.php?2719160486
VATAP (VA Technology Assessment Program) | Not available
VEC (Centre of Health Economics) | http://www.vec.gov.lv/english/default.html
ZonMw (The Medical and Health Research Council of The Netherlands) | http://www.zonmw.nl/