# Appendix B Systematic Review Search Strategy

Summary | Search strings
Recreated Philips et al. 2004 search{ Philips, 2004 198 /id}:
“Recommendation-related” terms | 1 | (checklist? or check list? or standards or standardi?ation or peer review$ or rules or critiquing or criteria or good or bad or correct$ or bias or fundamentals or recommend$ or best or strength$ or weakness$ or quality or qualities or validity or guideline? or validation or checkpoint?).ti.
“Recommendation-related” terms | 2 | (properly or critically appraise or problems or limitations or rating scale? or framework$ or protocol? or audit or principles or methodology$).ti.
“Recommendation-related” terms | 3 | (validate or validation or evaluating or properties or guidance or integrity or evaluation or pros or cons).ti.
“Recommendation-related” terms | 4 | or/1-3
“Modeling-related” terms | 5 | (decision adj (tree or triage or data or analytic or analysis)).ti.
“Modeling-related” terms | 6 | exp models, economic/ or exp models, econometric/
“Modeling-related” terms | 7 | (exp decision support techniques/ or exp data interpretation, statistical/ or exp decision theory/ or exp models, statistical/ or exp likelihood functions/ or exp linear models/ or exp logistic models/ or exp proportional hazards models/) and exp costs/ and cost analysis/
“Modeling-related” terms | 8 | ((economic? or pharmacoeconomic? or decision? or cost? or costing?) and model$).ti.
“Modeling-related” terms | 9 | (markov or crystal ball).ti.
“Modeling-related” terms | 10 | exp markov chain/
“Modeling-related” terms | 11 | or/4-9
Critical appraisal of models | 12 | ((markov model$ or economic model$ or mathematical model$ or cost$ model$ or pharmacoeconomic model$ or decision model$) adj2 (checklist? or check list? or standards or standardi?ation or peer review$ or rules or critiquing or criteria or good or bad or correct$ or bias or fundamentals or recommend$ or best or strength$ or weakness$ or quality or qualities or validity or guideline? or validation or checkpoint?)).ab.
Critical appraisal of models | 13 | ((markov model$ or economic model$ or mathematical model$ or cost$ model$ or pharmacoeconomic model$ or decision model$) adj2 (properly or critically appraise or problems or limitations or rating scale$ or good practice$ or framework$ or protocol$ or audit or principles or ethodology$)).ab.
Critical appraisal of models | 14 | ((markov model$ or economic model$ or mathematical model$ or cost$ model$ or pharmacoeconomic model$ or decision model$) adj2 (validate or validation or evaluating or properties or guidance or integrity or avoiding bias or evaluation or pros or cons)).ab.
Critical appraisal of models | 15 | ((decision tree or decision triage or decision data or decision analytic$ or decision analysis or crystal ball) adj2 (checklist? or check list? or standard$ or peer review$ or rules or critiquing or criteria or good or bad or correct$ or bias or fundamentals or recommend$ or best or strength$ or weakness$ or quality or qualities or validity or guideline? or validation or checkpoint?)).ab.
Critical appraisal of models | 16 | ((decision tree or decision triage or decision data or decision analytic$ or decision analysis or crystal ball) adj2 (properly or critically appraise or problems or limitations or rating scale$ or framework$ or protocol$ or audit or principles or methodology$)).ab.
Critical appraisal of models | 17 | ((decision tree or decision triage or decision data or decision analytic$ or decision analysis or crystal ball) adj2 (validate or validation or evaluating or properties or guidance or integrity or evaluation or pros or cons)).ab.
Critical appraisal of models | 18 | ((economic evaluation? or economic analysis or economic stud$ or economic submission?) and guideline$).ti.
Critical appraisal of models | 19 | or/12-18
Total Philips search | 20 | or/4, 11, 19
Additional terms added for this systematic review, restricted to targeted journals:
Targeted journals | 21 | Value in health.jn.
Targeted journals | 22 | (Health technology assessment or “Health Technology Assessment (Winchester, England)”).jn.
Targeted journals | 23 | Pharmacoeconomics.jn.
Targeted journals | 24 | Journal of Medical Economics.jn.
Targeted journals | 25 | Annals of Internal Medicine.jn.
Targeted journals | 26 | Medical Decision Making.jn.
Targeted journals | 27 | BMC Health Services Research.jn.
Targeted journals | 28 | Clinical Therapeutics.jn.
Targeted journals | 29 | European Journal of Health Economics.jn.
Targeted journals | 30 | (The Journal of the American Medical Association or jama).jn.
Targeted journals | 31 | (British Medical Journal or BMJ).jn.
Targeted journals | 32 | Current Medical Research & Opinion.jn.
Targeted journals | 33 | Health Economics.jn.
Targeted journals | 34 | Journal of Health Economics.jn.
Targeted journals | 35 | Medical care.jn.
Targeted journals | 36 | International Journal of Technology Assessment in Health Care.jn.
Targeted journals | 37 | BMC Medical Research Methodology.jn.
Targeted journals | 38 | Journal of Clinical Epidemiology.jn.
Targeted journals | 39 | Journal of general internal medicine.jn.
Targeted journals | 40 | American journal of managed care.jn.
Targeted journals | 41 | Journal of managed care pharmacy.jn.
Targeted journals | 42 | The European journal of health economics.jn.
Targeted journals | 43 | Journal of evaluation in clinical practice.jn.
Targeted journals | 44 | The Journal of the american board of family practice.jn.
Targeted journals | 45 | Statistics in medicine.jn.
Targeted journals | 46 | Archives of Internal Medicine.jn.
Targeted journals | 47 | Clinical Therapeutics.jn.
Targeted journals | 48 | Current Medical Research & Opinion.jn.
Targeted journals | 49 | The New England Journal of Medicine.jn.
Targeted journals | 50 | Lancet.jn.
Targeted journals | 51 | PLOS medicine.jn.
Targeted journals | 52 | Annual review of genomics.jn.
Targeted journals | 53 | Human genetics.jn.
Targeted journals | 54 | Population health metrics.jn.
Targeted journals | 55 | Radiology jn.
Targeted journals | 56 | Journal of the national cancer institute.jn.
Targeted journals | 57 | Health care management science.jn.
Targeted journals | 58 | (Canadian medical association journal or cmaj).jn.
Targeted journals | 59 | or/21-58
Recommendation-related terms, restricted to journals | 60 | (consensus or standard$ or framework$ or principle$ or committee$).mp. [mp=ti, ab, ot, nm, hw, ps, rs, ui, tx]
Recommendation-related terms, restricted to journals | 61 | 59 and 60
Recommendation-related terms, restricted to journals | 62 | (cost$ and (effectiv$ or utility or benefit) and (analy$ or model$)).mp. [mp=ti, ab, ot, nm, hw, ps, rs, ui, tx]
Recommendation-related terms, restricted to journals | 63 | exp cost-benefit/
Recommendation-related terms, restricted to journals | 64 | (decision and (analy$ or model$ or analy$)).mp. [mp=ti, ab, ot, nm, hw, ps, rs, ui, tx]
Recommendation-related terms, restricted to journals | 65 | exp decision support techniques/
Recommendation-related terms, restricted to journals | 66 | ((model and (microsimulation or dynamic or discrete event or simulation or state transition or agent based or infectious disease transmission or transmission or seir)) or computer simulation).mp. [mp=ti, ab, ot, nm, hw, kf, ps, rs, ui, tx]
Modeling-related terms, restricted to journals | 67 | or/62-66
Modeling-related terms, restricted to journals | 68 | 59 and 67
Additional terms, total | 69 | 61 or 68
Total (combined Philips search and additional terms) | 70 | 20 or 69
Restriction by publication date | 71 | limit 70 to yr = 1990 -Current