# Appendix A Acknowledgments

Clinical and Policy Advisory team (CaPA): Joshua Cohen (Tufts Medical Center), Peter Neumann (Tufts Medical Center), Stephen Pauker (Tufts Medical Center).

Technical Expert Panel (TEP): Eric Bass (Johns Hopkins University), Andrew Briggs (University of Glasgow), Robert Golub (Northwestern University), Douglas Owens (Stanford University), J. Sanford Schwartz (University of Pennsylvania), Milton Weinstein (Harvard University).

Stakeholder meeting attendees (stakeholders): Andrew Briggs (University of Glasgow), Martin Brown (Patient-Centered Outcomes Research Institute), Paul Coates (National Institutes of Health), Joshua Cohen (Tufts Medical Center), Mark Ebell (University of Georgia), Eric Feuer (National Institutes of Health), Rachael Fleurence (Patient-Centered Outcomes Research Institute), Scott Grosse (Center for Disease Control), Mark Helfand (Oregon Health & Science University), Mark Hltaky (Stanford University), Don Husereau (Institute of Health Economics), Karen Kuntz (University of Minnesota), Timothy Lash (Wake Forest University), Angela Lasher (U.S. Food and Drug Administration), Jeanne Mandelblatt (Georgetown University), Robert McDonough (Aetna), Peter Neumann (Tufts Medical Center), Deborah Olster (National Institutes of Health), Douglas Owens (Stanford University), Stephen Pauker (Tufts Medical Center), Diane Petitti (Arizona State University), Mark Roberts (University of Pittsburgh), James Rollins (Centers for Medicare and Medicaid Services), James Scanlon (U.S. Department of Health and Human Services), J. Sanford Schwartz (University of Pennsylvania), Uwe Siebert (University of Health Sciences, Medical Informatics, and Technology in Austria), Pamela Wescott (Foundation for Informed Medical Decision Making), Ann Zauber (Memorial Sloan-Kettering Cancer Center).

This manuscript reflects solely the opinions of the authors and does not reflect the opinions of AHRQ, the Department of Health and Human Services, meeting participants, or the institutions with which they are affiliated.