# Results

## Reviewer Characteristics

In the training sample, LR’s overall acceptance rate was 9.6 percent (of 795 citations screened in total) and PS’s was 12 percent (1,195 citations screened). Table 1 shows the rater agreement for a subsample of 400 citations that were screened in duplicate by the two reviewers.

Table 1 Inter-rater agreement training sample, 400 abstracts, original reviewer set

| LR Discard | LR Obtain Full Text | Total
PS Discard | 357 | 15 | 372
PS Obtain Full Text | 8 | 19 | 27
Total | 365 | 34 | 399

The independent reviewers agreed on 376/399 citations (94 percent). The inter-rater agreement (kappa) was 0.57. The overall acceptance rate in the training sample consisting of 1,591 unique citations was 12.6 percent. This is based on the cumulative reviewer decision; for 200 citations at least one reviewer indicated that the full text publication should be obtained.

In the primary validation sample of 400 citations, LR and PS served again as literature reviewers. In this reference sample, LR’s acceptance rate was 19.3 percent and PS’s was 11.8 percent. The independent reviewers agreed on 376/399 citations (94 percent). The inter-rater agreement (kappa) was 0.57. Table 2 shows the agreement between reviewers.

Table 2 Inter-rater agreement validation sample, 400 abstracts, original reviewer set

| LR Discard | LR Obtain Full Text | Total
PS Discard | 315 | 38 | 353
PS Obtain Full Text | 8 | 39 | 47
Total | 323 | 77 | 400

The overall acceptance rate (one or both reviewers indicated that the citation should be obtained as full text rather than discarded) in this sample was 21.3 percent. This was a statistically significantly higher acceptance rate than in the training sample (p<0.001).

To explore whether the reviewer behavior and prediction performance was unique to the training sample reviewer pair we added a second pair of reviewers (MD, SH) screening 400 different citations from the remaining dataset. In this second validation sample, MD’s acceptance rate was 17.5 percent and SH’s was 18 percent. Table 3 shows the agreement between reviewers for the 400 citations.

Table 3 Inter-rater agreement validation sample, 400 abstracts, new reviewer set

| MD Discard | MD Obtain Full Text | Total
SH Discard | 303 | 25 | 328
SH Obtain Full Text | 27 | 45 | 72
Total | 330 | 70 | 400

Both independent reviewers agreed on 348/400 citations (87 percent). The inter-rater agreement (kappa) was 0.55. The overall acceptance rate (one or both reviewers want to see the full text publication) in this reference sample was 24.3 percent.

### Predictions

The machine learning approach used the revFiewer decisions in the training sample to learn and to predict decisions. In a first step, the algorithm identifies terms that differentiate relevant from irrelevant citations. The process determines which terms are over- and which terms are under-represented in relevant citations (relevant citations are those that were selected by reviewers for further full text inclusion screening). The program has access to all fields and content of citations downloaded from electronic databases including MeSH tags.

Included citations used the terms “improving,” “patients,” “interventions,” “implementing,” and “staff” more often than citations that were considered irrelevant by the reviewers. The selection of terms may reflect that reviewers aimed to identify evaluations of interventions, i.e., studies reporting empirical data on (typically) patient outcomes. The terms “adequate,” “public,” “search,” “evolving,” and “consensus” were underrepresented in relevant citations. This selection appears to correlate with the exclusion of discussion papers and opinion pieces as reflected in the inclusion criteria. A list of the most statistically significant over- and underrepresented terms are shown in Appendix D Table 2.

#### To what extent is the algorithm able to model reviewers’ decisions in the training citation dataset?

We tested a number of statistical prediction algorithms and a number of strategies to identify the best model, i.e., maximizing specificity while maintaining sensitivity at an acceptable level. For the training data modeling purposes, a citation was declared relevant if at least one of the reviewers indicated that it should be obtained as full text.

The Augmented MeSH Approach did not work well in our application even on training data, since the MeSH feature vectors did not support the differentiation of relevant and irrelevant citations in the chosen quality improvement dataset. The approach's poor performance may have stemmed from the lack of designated MeSH terms for quality improvement publications. Furthermore, the remaining MeSH terms in the search output were not specific to quality improvement and were not useful to differentiate the citation pool.

However, both the lasso approach and SVM algorithms worked relatively well on the training data using the Text Mining Approach. SVM performed much better on the training data, while did rather poorly on test data. This may be due to the fact that SVM on the training data had 1,276 non-zero coefficients, while lasso had only 78 non-zero coefficients. Thus, SVM is over-fitting on the training data, which may have negatively affected its predictions. Reported results are therefore based on the lasso approach.

The final prediction model based on lasso with the threshold chosen to reduce work load (correctly detecting truly irrelevant citations) while maintaining a sensitivity of at least 85 percent (maintaining a high level of correctly identifying relevant citations – citations that reviewers chose to be obtained as full text). Figure 1 shows the receiver operating characteristic (ROC) curve for the training sample (1,591 citations screened by at least one reviewer).

Figure 1 Prediction performance training data (in-sample)

The figure shows a ROC curve for the training sample plotting the sensitivity against 1 minus the specificity. The area under the ROC curve is 0.7828. The figure indicates that to achieve a sufficient sensitivity (for this project determined to be 85%) low specificities have to be accepted.

The final model using the full dataset was able to predict the reviewers’ decisions with sufficient accuracy. However, when dividing the in-sample (training) data into subsets and cross-validating predictions across subsets, the mean achieved sensitivity was 83.5 percent with a corresponding specificity of 51.5 percent (PPV 19.9 percent).

#### To what extent is the algorithm able to extrapolate from the training sample to a large citation dataset?

The prediction model was then applied to extrapolate predictions for the remaining 7,804 titles and abstracts in the dataset. The model determined for each title and abstract whether the citation was likely to be discarded by a literature reviewer or selected to be obtained as full text. To validate the use of machine learning in systematic reviews this “out-of-sample” set was tested against reviewer decisions.

The following Table 4 shows the results for the original set of reviewers, LR and PS who also provided literature reviewer decisions for the training set. The reference set data are based on the combined decision across reviewers—at least one reviewer selected the citation as relevant (to be obtained as full text) so a true discard would have been rejected by both independent reviewers whereas a true obtain could have been selected by one or both reviewers. The prediction model was developed in the training, not this validation sample and reviewers were blind to the model predictions.

Table 4 Confusion matrix original reviewer pair (LR, PS)

| Predicted Discard | Predicted Obtain Full Text | Total
True Discard | 126 | 189 | 315
True Obtain Full Text | 8 | 77 | 85
Total | 134 | 266 | 400

The sensitivity and corresponding specificity were 90.6 percent and 40 percent with a PPV of 28.9 percent. The model missed 8/85 relevant citations. However, the model predicted that many more citations would be classified as “obtain” by the reviewers (266 predicted vs. 85 actually selected citations). The value in terms of work saved was 33.5 percent—a third of the search output could be discarded while maintaining a sensitivity of 90.6 percent.

A further application of the approach is to use the quantitative score to rank order the citations by relevance, for example to enable citations with a higher probability to be processed first. The algorithm determines a quantitative probability score for each of the identified citations. Ordering the citations in the primary reference sample (LR, PS) based on the probability score, 26/85 relevant citations (31 percent) would be found in the first 50 citations while 48/50 of the last citations are irrelevant (2 relevant citation would be missed). Screening the first 100 rank ordered citations will identify over half the relevant citations (45/85, 53 percent) while 97/100 of the last citations are irrelevant (3 citations missed). The quantitative score does not provide a perfect map of the citation sample but allows us to divide the dataset into parts with better odds of finding relevant citations.

We also tested how well the model predicted selections of independent reviewers not involved in the selection of the training data set to investigate how reviewer-specific the predictions are. Reviewers MD and SH screened a different random sample. The performance in this reference sample was very similar to the original reviewer set. Table 5 shows the confusion matrix.

Table 5 Confusion matrix new reviewer pair (MD, SH)

| Predicted Discard | Predicted Obtain Full Text | Total
True Discard | 145 | 158 | 303
True Obtain full text | 10 | 87 | 97
Total | 155 | 245 | 400

The resulting sensitivity was 89.7 percent with corresponding specificity of 47.9 percent and a PPV of 35.5 percent. The performance was only marginally less sensitive than for the reviewer pair that formed the basis of the training set. The results correspond to 38.7 percent of work saved.

The sensitivity and specificity for individual reviewers did not indicate that performance was notably better or worse for individual reviewers in the reference samples. Sensitivity ranged from 90.0 percent (corresponding specificity 44.8 percent, MD) to 97.9 percent (corresponding specificity 37.7 percent, PS).

The quantitative score results were replicated in this second reference sample (MD, SH): 31/97 relevant citations (32 percent) were included in 50 citations with the highest probability score while 48/50 of the lowest ranking citations are irrelevant (2 relevant citation would be missed) when ordering the citations by the quantitative prediction score. Screening the first 100 rank ordered citations will identify over half the relevant citations (54/97, 56 percent) while 95/100 of the last citations are irrelevant (5 citations missed).

Across both reference samples, the performance was 90.1 percent sensitivity, 43.9 percent specificity, 32.1 percent PPV and 36.1 percent work saved.

#### How well will a machine learning approach work in a complex and heterogeneous research field?

The tested machine learning approach aimed to predict decisions based on titles and abstracts, i.e., the first step in a systematic review after citations have been identified in electronic searches. Title and abstract screening is ultimately less reliable than full text decisions which is based on explicit inclusion and exclusion criteria typically reviewed in duplicate with conflict resolution. The applied prediction model for the title and abstract screening process uses the accumulated information across both independent reviewers—the final decision was “obtain” if at least one reviewer identified the citation as relevant. There were several disagreements amongst reviewers (training set: 23/399 citations; reference set LR, PS: 46/400; reference set MD, SH: 52/400). At the title and abstract screening stage, reviewers have to process a large amount of information in a short amount of time without defined inclusion criteria and based on very limited information (citation only). Hence, the reviewer’s decisions may be an imperfect gold standard.

We explored reviewer disagreements in a set of citations screened in duplicate (LR, PS; reference sample). Appendix D Table 3 shows the full citation plus the abstract of the 46 citations two reviewers disagreed on, meaning one reviewer indicated to obtain the citation as full text while the other decided to discard it. The disagreements were discussed in our quality improvement research team. The discussions showed that the source of disagreement was typically not a simple reviewer error (e.g., one of the two reviewers overlooked a piece of relevant information). An example is PMID 17530519, a publication on asthma treatment protocols in the emergency department which reported an electronic search indicating that the article is a literature review, not an evaluation of an individual study. The disagreement was sometimes based on the lack of information and both reviewers interpreting the limited information differently. An example is the decision whether PMID 17851382, a publication on caring for patients dying at home from heart failure, is likely to report on patient (or caregiver), provider behavior, or process of care health outcomes that can be linked to a quality improvement intervention in a health care delivery organization. However, in several cases reviewers conceptually disagreed whether the publication would meet inclusion criteria if obtained as full text based on the presented information. PMID 18410318, a study evaluating a program to enhance after-hour telephone communication between nurses and physicians, was eventually classified to be discarded but intense discussions evolved around the question whether the reported outcome “the percentage of calls that resulted in immediate evaluation by a physician” should be classified as a process of care health outcome. All reasons for discarding citations rather than obtaining these as full text are documented in Appendix D Table 3. The most frequent reason to discard publications after team discussions was the reported outcome, the lack of patient, provider behavior, or process of care health outcomes.

In order to explore the reliability of the reference standard and whether its reliability influences the validity in terms of test performance, we performed a subgroup analysis for those citations where both independent reviewers agreed and independently came to the same decision. Table 6 shows the confusion matrix for a subsample of citations with full agreement between reviewers across both reference samples (LR, PS and MD, SH).

Table 6 Confusion matrix subsample full agreement between reviewers

| Predicted Discard | Predicted Obtain Full Text | Total
True Discard | 271 | 347 | 618
True Obtain Full Text | 1 | 83 | 83
Total | 272 | 430 | 702

Note: Based on both reference samples (LR, PS; MD, SH)

The sensitivity increased to 98.8 percent when restricting to citations with full agreement amongst reviewers. The specificity remained at 43.9 percent and the PPV was 19.3 percent. The workload saving estimate was similar to the main analysis (38.7 percent).