# References

Altman RB, Bergman CM, Blake J, et al. Text mining for biology–the way forward: opinions from leading scientists. Genome Biology. 2008;9(Suppl 2):S7. [pmid: 18834498].
Aphinyanaphongs Y, Aliferis C. Text categorization models for identifying unproven cancer treatments on the web. Stud Health Technol Inform. 2007;129:968-72. [pmid: 17911859].
Balk EM, Moorthy D, Obadan NO, et al. Diagnosis and Treatment of Obstructive Sleep Apnea in Adults. Comparative Effectiveness Review No. 32. (Prepared by Tufts Evidence-based Practice Center under Contract No. 290-2007-100551). AHRQ Publication No. 11-EHC052-EF. Rockville, MD. Agency for Healthcare Research and Quality. 2011. www.effectivehealthcare.ahrq.gov/reports/final.cfm.
Cohen AM, Ambert K, McDonagh M. Cross-topic learning for work prioritization in systematic review creation and update. J Am Med Inform Assoc. 2009;16(5):690-704. [pmid: 19567792].
Cohen AM, Ambert K, McDonagh M. A Prospective Evaluation of an Automated Classification System to Support Evidence-based Medicine and Systematic Review. AMIA Annual Symposium proceedings. 2010:121-5. [pmid: 21346953].
Cohen AM, Hersh WR, Peterson K, et al. Reducing workload in systematic review preparation using automated citation classification. J Am Med Inform Assoc. 2006;13(2):206-19. [pmid: 16357352].
Dalal SR, Shekelle PG, Hempel S, et al. A Pilot Study Using Machine Learning and Domain Knowledge To Facilitate Comparative Effectiveness Review Updating, Methods Research Report. Prepared by the Southern California Evidence-based Practice Center under Contract No. 290-2007-10062-I). AHRQ Publication No. 12-EHC069-EF. Rockville, MD. Agency for Healthcare Research and Quality. September. 2012.
Danz M, Rubenstein L, Hempel S, et al. Identifying quality improvement intervention evaluations –is consensus achievable?. Qual Saf Health Care. 2010;19(4):279-83. [pmid: 20630931].
Deerwester S, Dumais S, Furnas G, et al. Indexing by Latent Semantic Analysis. J Am Soc Inf Sci. 1990;41(6):391-407.
EPOC: Cochrane Effective Practice and Organisation of Care Group. Welcome to the EPOC Ottawa Website. http://epoc.cochrane.org. Accessed April 2012.
Friedman J, Hastie T, Tibshirani R. Regularization paths for generalized linear models via coordinate descent. J Stat Softw. 2010;33(1):1-22. [pmid: 20808728].
Genkin A, Lewis DD, Madigan D. Large-scale Bayesian logistic regression for text categorization. Techometric. 2007;49(3):201-304.
Glanville JM, Lefebvre C, Miles JN, et al. How to identify randomized controlled trials in MEDLINE: ten years on. J Med Libr Assoc. 2006;94:130-6. [pmid: 16636704].
Hastie T, Tibshirani R, Friedman J. The elements of statistical learning: data mining, inference, and prediction. New York. Springer Verlag. 2009.
Hempel S, Rubenstein L, Shanman R, et al. Identifying quality improvement intervention publications. Implement Sci. 2011;6:85. [pmid: 21806808].
Jenkins M. Evaluation of methodological search filters—a review. Health Info Libr J. 2004;21:148-63. [pmid: 15318913].
O’Neil S, Rubenstein L, Danz M, et al. Identifying continuous quality improvement publications: what makes an improvement intervention ‘CQI’?. BMJ Qual Saf. Dec. 2011;20(12):1011-9. Epub 2011 Jul 4.
Porter M. An algorithm for suffix stripping. Program. 1980;14(3):130-7.
Rubenstein LV, Hempel S, Farmer M, et al. Finding order in heterogeneity: Types of quality improvement intervention publications. Qual Saf Health Care. 2008;17(6):403-8. [pmid: 19064654].
Shetty KD, Dalal SR. Using information mining of the medical literature to improve drug safety. J Am Med Inform Assoc. 2011;18:668-74. [pmid: 21546507].
Tibshirani R. Regression shrinkage and selection by Lasso. J R Stat Soc Ser C Appl Stat. Series B. 1996;58:267-88.
Vapnik VN. The Nature of statistical learning theory. New York. Springer-Verlag. 1995.
Wallace BC, Small K, Brodley C, et al. Active learning for biomedical citation screening. KDD ‘2010. Proceedings of the 16th ACM SIGKDD international conference on knowledge discovery and data mining. Washington, DC. ACM. 2010.
Wallace BC, Trikalinos TA, Lau J, et al. Semi-automated screening of biomedical citations for systematic reviews. BMC Bioinformatics. 2010;11:55. [pmid: 20102628].
Wei Y, Clyne M, Dolan SM, et al. GAPscreener: an automatic tool for screening human genetic association literature in PubMed using the support vector machine technique. BMC Bioinformatics. 2008;9:205. [pmid: 18430222].