# Methods

## Dataset

We used a PubMed and MEDLINE (Ovid) based search output that aimed to identify quality improvement and continuous quality improvment publications. The search strategy is documented in Appendix B. It combined several strategies to identify quality improvement citations by using a general search strategy to identify novel approaches as well as searching for specific, known quality improvment interventions and components. It aimed to identify approaches covered by the Cochrane Effective Practice and Organisation of Care Group registry (EPOC, 2012) and used continuous quality improvement terms to identify relevant studies. It covered a 5 year publication period (2004 to 2009) and was limited to English-language publications but was not limited to specific clinical fields, interventions, or outcomes.

The search strategy produced 9,395 hits of which only a small number will be relevant to quality improvement in general, and to evaluations of quality improvement interventions in particular. This filter problem is typical for the research field and a low base rate of potential includes has to be assumed (Hempel et al., 2011). The search yield is stored in an EndNote library containing all downloadable information available from PubMed and MEDLINE accessed through the Ovid interface.

## Initial Procedure

The initial procedure for this project involved having two reviewers (Drs. Lisa Rubenstein [LR] and Paul Shekelle [PS]), both experts in quality improvement research, screen a fraction of the search output to identify potentially relevant publications, in this case evaluations of quality improvement interventions. Each reviewer’s decision was recorded for the sample; the decision as this point is only whether to obtain the full text of the publication or to discard it. Discarding the citation means that the reviewers deemed it unlikely that the full text publication will meet the full text inclusion criteria for quality improvment evaluation publications shown in Appendix C. The full text inclusion criteria require a publication to report on a health care delivery organization; to include data on the effectiveness, impacts, or success of an intervention; to report on patient, provider behavior, or process of care health outcomes; and to evaluate an intervention that aimed to change how delivery of care is routinely structrured.

The selected training sample represents a small percentage (17 percent) of the total search output (1,600 titles and abstracts, where abstracts were available), quasi-randomly selected (ordered by first page number, i.e. 1, 11, 111 etc.) from all titles and abstracts identified in the electronic searches. The number of titles and abstracts was chosen based on workload considerations and were presented to reviewers in batches of 400 titles and records. The sample citations were screened by one or both of the expert reviewers independently. LR screened 800 titles and abstracts, PS 1,200, both reviewers screened 400 titles in duplicate; 9 duplicate citations were subsequently found and removed, leaving 1,591 unique citations in the training set.

## Machine Learning Approach

The overall machine learning approach applied to this project approach uses the information from the literature reviewers to learn and to predict the reviewer’s decisions. A training set (1,591 coded abstracts) was used to empirically model screening decisions as a function of article characteristics (i.e., article feature vectors); the resulting model is then used to predict citation screening decisions in the test set. The text analysis program had access to all information that can be downloaded from the database MEDLINE accessed through Ovid, and a PubMed search including database categorizations (MeSH terms). We considered two approaches for constructing these feature vectors: one based solely on MeSH and another based on text characteristics.

The first approach (“Augmented MeSH Approach”) had achieved good performance in testing on drug comparative effectiveness reviews (Dalal et al., in press). It primarily relies on extracting variables from a limited number of relevant MeSH headings and subheadings, as well as a few metadata of the citation (e.g., whether “quality improvement” is in the title) as binary feature vectors. We located relevant MeSH terms and subheadings by matching terms within the search strategy to terms within the MeSH database.

The second approach, which we call “Text Mining Approach,” solely uses words from the articles' titles and abstracts as feature vectors. In this approach, each title-abstract is represented by a vector of frequencies of each of the words in the title-abstract. This document corpus yielded a vocabulary of 20,000+ words; to reduce the dimensionality of these feature vectors, we removed various common verbs and nouns (e.g., “is,” “are,” “the”). Further, since there can be many different forms of words, we reduced them to their common grammatical roots (e.g., follow, follows, following, etc., becomes follow) using word stemming (Porter 1980). Finally, we discarded all the terms which occurred less than four times in the training data (the 1,591 manually reviewed titles and abstracts). Based on this we created a term document matrix consisting of 3,072 terms (the feature vectors) and 9,395 documents (all of the abstracts and titles in the test dataset).

Due to the size of the feature vectors we applied two prominent algorithms for our analysis and tested their performance: the lasso shrinkage and selection method (Friedman et al., 2010; Tibshirani, 1996), and a method for finding an optimal separating hyper plane (SVM, see Vapnik, 1995). The lasso algorithm minimizes the usual sum of squared errors, with a bound on the sum of the absolute values of the coefficients. This method shrinks coefficients of less important variables to zero, resulting in fewer variables with better predictive power. The shrinkage factor is determined by a tenfold cross-validation of the entire training data. We also tested an SVM-based approach, which distinguishes between relevant and irrelevant articles by finding the optimal separating hyperplane for distinguishing between the two clusters of feature vectors (relevant and irrelevant). As with lasso, this was developed on training data and then used to predict out-of-sample citations in the reference samples (see also Hastie et al., 2009; Vapnik, 1995).

## Predictions

The predictive model was first developed to differentiate relevant and irrelevant titles and abstracts in the training set (1,591 citations). In a next step, the model was then applied to the remaining citations (7,804 citations after removal of duplicates). Two parameters were generated:

- Quantitative prediction
  ○ A likelihood score expressing the level of relevance for each citation in the search output based on the selected prediction model
- Qualitative prediction
  ○ A cutoff score determining for each included citation whether it should be discarded or obtained for full text review based on the selected prediction model

The quantitative score takes the word frequency and similarities of relevant studies into account when predicting from the training set. Some citations will be more clearly irrelevant than others or are more likely to be relevant than others. The determined cutoff divides the sample qualitatively into a class of relevant, and a class of irrelevant citations.

A machine learning approach may put emphasis onto different kinds of predictive performance measures depending on its purpose and the cutoff can be chosen accordingly. Individual performance parameters are not independent of each other and there will be a trade-off between sensitivity and specificity. The selected approach may primarily aim to weed out irrelevant citations (specificity) to reduce workload, accepting that a noticeable number of relevant studies will be missed. Another application may put more emphasis on ensuring that no true positives will be missed, allowing a greater threshold of irrelevant citations (false positives) so that truly relevant citations will not be missed. The chosen cutoff aimed to reduce workload while maximizing sensitivity to the extent possible. In this instance, we deemed a sensitivity of 85 percent to be acceptable for the study purpose.

## Predictive Performance Test

### Reference Samples

The critical test for the machine learning approach is whether the model can extrapolate from the training sample to the remaining large number of citations. Therefore we sampled the remaining titles and abstracts and literature reviewers screened these for relevance, and then compared the reviewer decisions with the prediction model results.

The first set of literature reviewers were the same quality improvement experts that provided the training set decisions. The reviewers screened the citations in a random order, blind to the model predictions, for the quantitative as well as the qualitative score. Four hundred citations were screened in duplicate. Both literature reviewers reviewed the citations in the reference samples independently. An additional set of reviewers also screened a literature sample. Drs. Danz (MD) and Hempel (SH), both familiar with full text screening of quality improvement abstracts but not involved in the training data, also independently screened a sample of 400 citations from the remaining dataset.

### Analysis

We compared the predictions with the reviewer’s decision creating a confusion matrix, a 2×2 table showing correctly and incorrectly classified titles and abstracts, i.e., true and false negatives and positives. The literature reviewers form the gold standard which is compared with the algorithm’s prediction according to a given threshold. The basic table based on the accumulated reviewers’ decisions is shown in Appendix D Table 1. True negatives are citations correctly predicted to be discarded, false negatives are citations predicted to be discarded but one or both reviewers indicated they should be obtained, true positives are those predicted and eventually chosen by one or both reviewers to be obtained as full text, and false positives indicate a prediction to obtain the citation when in fact literature reviewers discarded the citation. The confusion matrix cells are not balanced due to the large number of irrelevant publications in each search output. We estimated from previous searches that only about 10 to 20 percent of titles and abstracts tend to be relevant and are pursued further; all other citations are discarded.

In the main validity analysis a citation is considered relevant (decision: obtain as full text) if at least one of the two reviewers has deemed it relevant. This includes a higher number of relevant titles and abstracts than based on the individual reviewer’s decisions given that individual reviewers do not perfectly overlap in their relevance decisions at the title and abstract stage. In addition, we explored the effect of individual reviewers and the reliability of the reference standard (the accumulated reviewer decisions). We calculated the rater agreement by computing the total agreement as well as the kappa statistic for this agreement between the two quality improvement experts. In addition, performance based on individual reviewer decisions was explored. Sources of disagreements between literature reviewers were identified, further explored, and reconciled. The impact of reviewer disagreements was explored through a subgroup analysis of citations with full agreement between independent reviewers.

We computed information retrieval performance measures for the sample used to train the model as well as for the remaining citations in the search output. The performance from the training data shows the potential of the algorithm in modeling reviewers’ decisions. The performance data for the remaining large dataset compared with reviewer screening of selected samples, provides information whether the algorithm can extrapolate from the training data sample to a large number of citations.

To document the predictive performance, we computed common composite scores, such as the sensitivity (recall, proportion of true positives correctly detected), the specificity (proportion of true negatives correctly detected), and the positive predictive value (precision, ratio of true positives to combined true and false positives) to characterize the machine learning method’s performance. Sensitivity is a central variable in this context because the primary aim of the title and abstract screening phase in systematic reviews is obtaining all pertinent studies. However, perfect sensitivity can be reached by declaring all citations relevant, which would entail obtaining almost 10,000 publications for full text review in this case. Therefore, we (and other systematic review researchers) consider the balance between true and false positives in both manual title and abstract screening and machine learning applications. Finally, we determined the proportion of workload (literature search screening of both relevant and irrelevant citations) that might have been avoided had the predictive model been used exclusively.