# Acknowledgements

We would like to thank Suchitra Iyer, AHRQ Project Officer, for her patience and helpful comments throughout the project; Aneesa Motala and Tanja Perry for assistance with data management and manuscript; Jeremy Miles for statistical assistance; Roberta Shanman for the literature searches; and Miriam de Kleijn for contributions to team discussions on quality improvement.