# Discussion

The project aimed to answer the following question: What are the performance outcomes of a machine learning process when assisting in the title and abstract inclusion screening process of a systematic review on quality improvement? We found that the predictive performance was 90.1 percent sensitivity, 43.9 percent specificity, and 32.1 percent PPV. The corresponding work saved was 36.1 percent if applied. The performance might be associated with reviewer agreement: a subgroup analysis restricted to titles and abstracts that both reviewers agreed on showed a sensitivity of 98.8 percent (specificity 43.9 percent).

In particular, we set out to answer the following questions:

- To what extent is the algorithm able to model reviewers’ decisions in the training citation dataset?
- To what extent is the algorithm able to extrapolate from the training sample to a large citation dataset?
- How well will a machine learning approach work in a complex and heterogeneous research field?

The questions arise from the nature of the data (titles and abstract inclusion screening decisions), the process (reviewers screening an arbitrary fraction of the search output), and the nature of the research field (quality improvement).

First, in this project we attempted to predict literature reviewers’ decisions at the title and abstract stage. Reviewers did not yet have the chance to see the full text publication but need to decide whether the citation has potential to meet full text inclusion criteria. Modeling reviewers’ decisions at the title and abstract stage is distinctly different from modeling full text screening decisions. The achieved results show less promise than achieved when predicting full text decisions (see Dalal et al., in press). The gold standard and data used to train the prediction model are less reliable than full-text decisions which are based on decisions reconciled between two reviewers or a review team and screened against documented, explicit inclusion and exclusion criteria. Citations are selected based on their potential, which involves educated guesses about the nature of the full text publication. Individual reviewers may not necessarily agree and come to different decisions about the citation. In the presented work, disagreements between reviewers were not primarily based on errors by individual reviewers. Disagreement evolved from different interpretations of the limited information (title and abstract only) and in addition, conceptual disagreements between reviewers about the reported information were apparent and remained to some extent even after extensive team discussions. This suggests lack of reliability of the gold standard which may well influence the predictive validity of the approach; according to classical test theory, reliability is a necessary condition for validity. As shown, we explored the impact of the reliability of the gold standard in a subgroup analysis by restricting to citations with reviewer agreement and found that the sensitivity of the prediction model increases considerably. While some amount of disagreement cannot be avoided and is likely to be rooted in the nature of the data (decisions have to be made based on limited information), for the purpose of training a prediction model, reviewers may have to spend time on reconciling conceptual disagreements to increase the reliability and validity of the model. We have shown elsewhere that implicit agreement on quality improvement cannot be assumed (Danz et al., 2010). Performance results may improve in a less heterogeneous research field, for example where quality improvement interventions evaluations are limited to a set of specific interventions, study designs, or outcomes.

In addition to modeling decisions in the training set, the main task of the machine learning approach is to extrapolate to the remaining search output. Reviewers screen only a fraction of the search output to train a prediction model. The results indicate reasonable sensitivity but sensitivity coefficients and estimated workload savings were moderate; machine learning approaches have been shown to achieve a 50 percent workload reduction including our own work (e.g., Cohen et al., 2006; Dalal et al., in press; Wallace, Trikalinos, et al., 2010). However, predictive performance was not worse than estimated in the training dataset when applying cross-validation tests by artificially dividing the initial sample into training and test tests. Future machine learning applications may be able to incorporate a flexible rather than a static approach to determine a prediction model. Wallace, Small, et al. (2010) report the use of an interactive training approach where reviewers train the model interactively by providing decisions on titles and abstracts that have been selected as being most informative rather than using a random sample of titles and abstracts. Furthermore, we used a fixed number of titles and abstracts for the training dataset based on reviewer burden. A flexible approach may allow frequent feedback regarding the success of the prediction model, information whether more training data are needed, or predictions regarding the maximum achievable model success. Thus, reviewers would know early on whether to proceed with the training process: some topics tend to be more suitable for machine learning approaches than others (see also Cohen et al., 2006).

We also explored the extent of specific reviewer calibration. Two specific reviewers served as trainers in the training set. The prediction model aimed to learn and predict the decisions of two specific reviewers and the model may be distinctly calibrated towards these two experts. However, we found that the predictive performance was not noticeably better for reviewers that served as trainers; results were very similar for a second set of expert reviewers. There was however evidence that reviewer behavior had changed between the training and the test stage. Most noticeably we saw that the acceptance rate of citations (the proportion of citations deemed relevant) was higher in the reference samples than in the original training sample. By the time reference samples were drawn, reviewers may have had a refined understanding of the kind of studies that should be included in the review.

We chose the example of quality improvement and aimed to identify intervention evaluations that aimed to improve the way health care is delivered. We have shown in prior publications that quality improvement is difficult to define; the field is characterized by heterogeneous interventions, a wide range of study designs, and study outcomes (Danz et al., 2010; O’Neil et al., 2011; Rubenstein et al., 2008). Even when features of quality improvement are agreed, the operationalization of features can remain a source of disagreements (see e.g., Danz et al., 2010). We explored a set of reviewer disagreements to understand whether the training process when developing the prediction model can be improved. Extensive team discussion showed that disagreements are often based on conceptual issues, for example about the nature of eligible outcomes, rather than simple reviewer errors, for example overlooking a detail in the title or abstract of the citation. The subgroup analysis for citations with full agreements showed that predictive validity can increase, suggesting that in these kind of machine learning approaches, false negatives (missing pertinent studies) as well as false positives (selecting citations that are not eligible for inclusion in the review) should be explored and reconciled where possible to improve the training process.

Unlike in previous work (Dalal et al., in press), in the current machine learning application MeSH terms were not used to differentiate relevant from irrelevant citations; the selected prediction model was based on text words. The dataset was the result of a carefully developed electronic search strategy already designed to maximize sensitivity and specificity where possible. Were MeSH terms easily available, these would have been considered in the original search strategy and integrated as a further filter. However, there is no designated MeSH term for quality improvement publications, which generally hinders accessibility of quality improvement evidence (Hempel et al., 2011). The reliance on MeSH terms can be a problem for newer citations and non-PubMed citations because such citations will need to be evaluated by systematic review researchers regardless of when such controlled language is added to the citation; therefore, a text-only strategy can be advantageous in machine learning assisted reviews.

The evaluation of the predictive model focused primarily on the determined qualitative cutoff (the citation is either predicted to be relevant or to be irrelevant) and resulting confusion matrix results and sensitivity and specificity. However, the developed approach can also determine a score for each citation quantifying the likelihood of relevance. This feature enables a better management of citations and the likelihood score can be used to prioritize citations or to determine the order in which citations are screened. Similarly, Balk et al. (2011) used a computerized screening program to prioritize citations identified in a search on the diagnosis and treatment of sleep apnea so that most relevant citations were processed first in the course of the review.

Our study tested a general approach of integrating machine learning in a systematic review process. The developed prediction model may be used as an additional, refined search algorithm for quality improvement intervention studies complementing electronic searches. However, the general tested machine learning approach was designed to assist an ongoing systematic review process, acknowledging that future reviews will synthesize other literature and will have other review-specific requirements which an equally tailored machine learning approach will need to address. How machine learning approaches are applied in practice has to be decided for each review. Applications may follow a static or interactive training model and different algorithms may need to be tested to find the most promising approach for each review topic. The machine learning decisions may be used to prioritize the screening order, may replace one of the two literature reviewers in the inclusion screening process, or may replace both reviewers after training if sufficient confidence in the automated process can be established.