# Conclusion

Machine learning approaches applied in systematic reviews of complex research fields such as quality improvement may assist in the title and abstract inclusion screening process. Machine learning approaches are of particular interest considering steadily increasing search outputs and accessibility of the existing evidence is a particular challenge of the research field quality improvement. Increased reviewer agreement appeared to be associated with improved predictive performance.