# Background

Outputs from electronic database searches for systematic reviews may contain tens of thousands of publications, despite progress in electronic search filter development. The reasons for this include the general increase in publication volumes, the complexity of the review questions requiring a diverse set of studies, and review areas that do not allow the restriction to high level of evidence studies such as randomized controlled trials (RCTs). These electronic searches typically yield far more citations than are relevant and selected for full text scrutiny.

Literature reviewers spend a substantial amount of time screening titles and abstracts to identify potentially relevant studies. Screening large search outputs is a lengthy process requiring considerable reviewer resources for a repetitive task that nonetheless requires conscientious and diligent work from expert reviewers. In this first step of inclusion screening, the title and abstract stage, reviewers do not make decisions about inclusion in a review. The cognitive decision reviewers have to make at this stage is whether a publication is worth screening as a full text publication because there is a chance that the publication will meet inclusion screening criteria. The decision at this stage of the review is whether to obtain full text or whether to discard. For the most part, this decision is an educated guess because the reviewers do not have the full information accessible that is available in the full text of the publication. At this review stage, reviewers are over-inclusive, and disagreements between different independent reviewers are typically not reconciled. The primary aim of this screening process is to ensure that pertinent studies are not missed. An incomplete set of eligible studies threatens the validity of the systematic review and the integrity of the review process. However, in systematic reviews additional sources are available to identify pertinent studies (e.g., reference mining of included studies, apart from the electronic database search).

In this project we assess a literature screening process that uses machine learning. Information technology approaches are being integrated in a number of research fields and the general purpose and approach vary. Altman et al. (2008) summarize opinions from leading scientists in biology; their responses highlighted the possibility of fusing literature and biological databases through text mining. Wei et al. (2008) published an automatic tool for screening human genetic association publication records exported from PubMed. Aphinyanaphongs and Aliferis (2007) used text categorization models to identify Web pages that make unproven cancer treatment claims. Information retrieval technologies are also being developed and tested for systematic review applications, primarily aiming to reduce the workload for literature reviewers by reducing the number of citations that have to be screened manually (e.g., Cohen et al., 2010; Cohen et al., 2009; Wallace, Small, et al., 2010; Wallace, Trikalinos, et al., 2010). Cohen et al. (2006) described an automated method to classify citations potentially relevant to 15 systematic drug class reviews. The model attempted to predict which articles contained high-quality, drug class-specific evidence. Results varied by topic; in some cases a 50 percent reduction of articles needing manual review was achieved. Balk et al. (2011) used a computerized screening approach to reduce the number of abstracts needed to manually screen prior to starting subsequent steps of the systematic review by 50 percent; all abstracts were eventually screened during the course of the review but no further relevant abstracts were identified.

Different approaches to differentiate citations have been explored. Wallace, Trikalinos, et al. (2010) used a Support Vector Machine (SVM) approach and reported that the number of manually screened publications can be reduced by between 40 and 50 percent for three systematic review topics. Multiple regression models and discriminant function approaches are popular in related fields trying to refine search filters for electronic databases (e.g., Glanville et al., 2006). Other text categorization approaches use Bayesian logistic repression (Genkin et al., 2007) and latent semantic indexing (LSI; Deerwester et al., 1990).

Machine learning methods may be particularly important in facilitating reviews of complex research areas such as quality improvement. Quality improvement interventions aim to improve the way health care is delivered. Quality improvement is a research field that is characterized by heterogeneous interventions, a wide range of study designs, and study outcomes (e.g., Danz et al., 2010; O’Neil et al., 2011; Rubenstein et al., 2008), and it is more challenging to search than (for example) classic drug studies. Electronic search strategies for quality improvement are particularly challenging, producing large search outputs with limited success in retrieving pertinent studies when restricted to a manageable search yield, such as 50,000 citations per database (Hempel et al., 2011). Electronic search filter development has been successful for methodological study designs such as RCTs (see e.g., Jenkins, 2004), but quality improvement evaluations employ a variety of study designs and searches that cannot be restricted to RCTs alone (see e.g., Rubenstein et al, 2008). Quality improvement interventions can encompass a large number of approaches, and literature searches are often designed to identify well-known as well as novel approaches and not a set of prespecified interventions. In addition, outcomes are often institution and intervention-specific and can also encompass a large number of possible measures. Finally, there is no MEDLINE Subject Heading (MeSH) term that allows the parsimonious identification of quality improvement publications in the most relevant database (MEDLINE).

We applied a machine learning approach that has been developed in our institution as part of a research program to explore the facilitation of research with novel information technology. Variations of the approach have been utilized for diverse research questions and applications (see e.g., Shetty and Dalal, 2011). The particular approach is designed to assist the process of ongoing systematic reviews. A machine learning approach has also recently been tested to assist in updates of systematic reviews (Dalal et al., in press). Systematic reviews require frequent updates given that the evidence base can change quickly in a short amount of time with medical developments and the publication of new research studies. The approach indicated reduced workload associated with screening updated search results for all relevant efficacy/effectiveness and adverse event articles by more than 50 percent with minimal or no loss of relevant articles. The validation process for the review update application concentrates on the model’s predictions of the full text inclusion screening decision in comparison to literature reviewers’ decisions. However, a machine learning approach may also be able to assist the regular inclusion screening process in systematic reviews.

## Objectives and Key Questions

The aim of this project was to test a machine learning approach for literature reviewers’ decisions at the title and abstract inclusion screening stage of a systematic review to identify published articles evaluating quality improvement—which citations from an electronic search output should be obtained as full text and screened further. To test the validity of the approach we compared the computer-generated prediction algorithm against reference samples screened by experts in quality improvement. The project aimed to answer the following question:

- What are the performance outcomes of a machine learning process when assisting in the title and abstract inclusion screening process of systematic reviews?

In particular, we were interested in the following questions:

- To what extent is the algorithm able to model reviewers’ decisions in the training citation dataset?
- To what extent is the algorithm able to extrapolate from the training sample to a large citation dataset?
- How well will a machine learning approach work in a complex and heterogeneous research field?

Appendix A Figure 1 outlines the proposed approach and its validity testing in detail. In the first step, literature reviewers screen a sample of the search output and decide which titles and abstracts should be obtained and screened as full text and which should be discarded. In a second step, an algorithm is developed that aims to learn and construct a model based on the reviewers’ decisions. Different methods to differentiate relevant and irrelevant publications and reviewer effects were explored. Once learned, the selection model can be applied to an essentially unlimited number of publications. In a third step, the algorithm is applied to the entire search output to predict which titles and abstracts will be selected. The performance in the final citation dataset may be markedly different from the training set performance because the algorithm has to extrapolate from the training set decision to a different, larger sample. Novel interventions not included in the training sample may be missed in the final citation dataset as the model will not have had the opportunity to learn about these. In a fourth step to validate the machine learning approach, the literature reviewers sample the remaining titles and abstracts (publications from the entire search output that were not part of the training set) and screen these for inclusion (that is, decide whether they should be obtained and screened as full text or discarded). In a final step, the algorithm’s predictions are compared with the reviewers’ decisions; for the training dataset as well as the remaining, out of sample, titles and abstracts.