# Inclusion Screening Form for Publications Obtained as Full Text

Full Text 4Q Screener