# Search Strategy

DATABASE SEARCHED & TIME PERIOD COVERED: MEDLINE ON OVID – 2004–2009

LIMITERS: ENGLISH ONLY

SEARCH #1 + MESH TERMS FOR “QUALITY”:

(quality and (improv* or enhance*) and (interven* or initiative* or strateg* or program* or collaborative* or process*)).mp. [mp=title, original title, abstract, name of substance word, subject heading word]

AND

(quality of health care or quality assurance, health care or quality indicators, health care or health plan implementation).sh. or organizational change.mp. or organizational structure.mp. or organizational innovation/[mp=title, original title, abstract, name of substance word, subject heading word]

NUMBER OF RESULTS: 4628

SEARCH #2:

149 (quality adj5 (improv* or enhance*) adj5 (interven* or initiative* or strategy or program or programme or collaborative* or process)).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
150 limit 149 to (english language and yr="2004 -Current")

NUMBER OF RESULTS: 1693

EPOC SEARCH FILTER:

2 exp *education, continuing/
3 (education$ adj2 (program$ or intervention? or meeting? or session? or strateg$ or workshop? or visit?)).tw.
4 (behavio?r$ adj2 intervention?).tw. or pamphlets/or (leaflet? or booklet? or poster? or pamphlet?).tw.
5 (((written or printed or oral) adj information) or (information$ adj2 campaign)).tw.
6 (education$ adj1 (method? or material?)).tw.
7 advance directives/or outreach.tw. or ((opinion or education$ or influential) adj1 leader?).tw.
8 (facilitator? or academic detailing or consensus conference?).tw. or *guideline adherence/or practice guideline?.tw.
9 (guideline? adj2 (introduc$ or issu$ or impact or effect? or disseminat$ or distribut$)).tw.
10 ((effect? or impact or evaluat$ or introduc$ or compar$) adj2 training program$).tw.
11 *reminder systems/or reminder?.tw. or (recall adj2 system$).tw. or (prompter? or prompting).tw. or algorithm?.tw.
12 *feedback/or feedback.tw. or chart review$.tw. or ((effect? or impact or records or chart?) adj2 audit).tw.
13 (compliance or marketing).tw.
14 6 or 11 or 3 or 7 or 9 or 12 or 2 or 8 or 4 or 13 or 10 or 5
16 exp *reimbursement mechanisms/
17 fee for service.tw. or *capitation fee/or *"deductibles and coinsurance"/or cost shar$.tw.
18 (copayment? or co payment? or (prepay$ or prepaid or prospective payment?)).tw.
19 *hospital charges/or formular$.tw. or fundhold$.tw. or *medicaid/or *medicare/or blue cross.tw.
20 18 or 19 or 16 or 17
21 *nurse clinicians/or *nurse midwives/or *nurse practitioners/or (nurse adj (rehabilitator? or clinician? or practitioner? or midwi$)).tw.
22 *pharmacists/or clnical pharmacist?.tw. or paramedic?.tw. or *patient care team/or exp *patient care planning/or (team? adj2 (care or treatment or assessment or consultation)).tw.
23 (integrat$ adj2 (care or service?)).tw.
24 ((care adj2 (coordinat$ or program$ or continuity)) or (case adj1 management)).tw.
25 exp *ambulatory care facitilites/or *ambulatory care/
26 exp *ambulatory care facilities/
27 25 or 22 or 21 or 24 or 26 or 23 or 20
28 *home care services/or *hospices/or *nursing homes/or *office visits/or *house calls/
29 *day care/or *aftercare/or *community health nursing/or (chang$ adj1 location?).tw.
30 (domiciliary or (home adj1 treat$) or day surgery).tw. or *medical records/or *medical records systems, computerized/or (information adj2 (management or system?)).tw.
31 *peer review/or *utilization review/or exp *health services misuse/
32 28 or 30 or 31 or 29
33 *physician's practice patterns/or quality assurance.tw. or *process assessment/[health care]
34 *program evaluation/or *length of stay/or (early adj1 discharg$).tw. or discharge planning.tw.
35 (((offset or triage).tw. or exp *"Referral and Consultation"/) and "consultation"/) or *drug therapy, computer assisted/
36 near patient testing.tw. or *medical history taking/or *telephone/or (physician patient adj (interaction? or relationship?)).tw.
37 *health maintenance organizations/or managed care.tw. or (hospital? adj1 merg$).tw.
38 35 or 33 or 34 or 36 or 37
39 ((standard or usual or routine or regular or traditional or conventional or pattern) adj2 care).tw.
40 (program$ adj2 (reduc$ or increas$ or decreas$ or chang$ or improv$ or modify$ or monitor$ or care)).tw.
41 (program$ adj1 (health or care or intervention?)).tw.
42 ((effect? or impact or evaluat$ or introduc$ or compar$) adj2 treatment program$).tw.
43 ((effect? or impact or evaluat$ or introduc$ or compar$) adj2 care program$).tw.
44 ((effect? or impact or evaluat$ or introduc$ or compar$) adj2 screening program$).tw.
45 ((effect? or impact or evaluat$ or introduc$ or compara$) adj2 prevent$ program$).tw.
46 (computer$ adj2 (dosage or dosing or diagnosis or therapy or decision?)).tw.
47 ((introduc$ or impact or effect? or implement$ or computer$) adj2 protocol?).tw.
48 ((effect? or impact or introduc$) adj2 (legislation or regulations or policy)).tw.
49 39 or 40 or 41 or 48 or 47 or 42 or 46 or 45 or 43 or 44
50 (randomized controlled trial or controlled clinical trial).pt. or intervention studies/or experiment$.tw.
51 ((time adj series) or (pre test or pretest or posttest or post test)).tw.
52 random allocation/or impact.tw. or intervention?.tw. or chang$.tw. or evaluation studies/or evaluat$.tw. or effect?.tw.
53 comparative study.pt.
54 52 or 50 or 53 or 51
55 animal/
56 human/
57 55 NOT (55 and 56)
58 38 or 27 or 32 or 49 or 20 or 14
59 54 not 57
60 59 and 58
61 limit 60 to review
62 60 not 61
63 meta-analysis.pt.
64 62 not 63
65 (quality of health care or quality assurance, health care or quality indicators, health care or health plan implemenation).sh.
66 health plan implementation.sh.
67 66 or 65
68 67 and 64
69 68
70 limit 69 to yr="2004 -Current"
83 (quality and (improv* or enhance*) and (interven* or initiative* or strateg* or program* or collaborative* or process*)).mp.
84 limit 83 to (english language and yr="2004 – 2009")
85 limit 68 to (english language and yr="2004 -Current")
104 from 85 keep 3801–3943
105 38 or 27 or 32 or 49 or 20 or 14
106 105 and 54
107 106 not 57
108 limit 107 to review
109 107 not 108
110 meta-analysis.pt.
111 109 not 110
  AND
112 (quality of health care or quality assurance, health care or quality indicators, health care or health plan implementation).sh. or organizational change.mp. or organizational structure.mp. or organizational innovation/[mp=title, original title, abstract, name of substance word, subject heading word]
113 112 and 111
114 limit 113 to (english language and yr="2004 -Current")

NUMBER OF RESULTS: 4587

CQI SEARCH

161 pdsa.ti,ab. or plan-do-study-act.mp. or plan do study act.mp. [mp=title, original title, abstract, name of substance word, subject heading word]
162 limit 161 to (english language and yr="2004 -Current")
163 pdca.ti,ab. or plan-do-check-act.mp. or plan do check act.mp. [mp=title, original title, abstract, name of substance word, subject heading word]
164 define-measure-analyze-improve-control.mp. or dmaic.ti,ab. or dmadv.ti,ab. or define-measure-analyze-design-verify.mp. [mp=title, original title, abstract, name of substance word, subject heading word]
165 ((iterative adj cycle) or (rapid adj cycle) or (small adj test adj2 change)).mp. or deming.ti,ab. or taguchi.ti,ab. or kansei.ti,ab. [mp=title, original title, abstract, name of substance word, subject heading word]
166 (six-sigma or (six adj sigma)).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
167 total quality management.ti,ab.
168 ((quality adj function adj deployment) or (house adj2 quality) or (quality adj circle) or (breakthrough adj series)).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
169 ((institute adj2 healthcare adj improvement) or (iso adj "9004") or (iso adj 15594*)).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
170 kaizen.ti,ab. or (toyota adj production adj system).mp. or (toyota adj a3).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
171 ((lean adj manufacturing) or (lean adj production) or (lean adj healthcare) or (lean adj health adj care) or (lean adj health adj service) or (lean adj healthcare adj service) or (lean adj health adj care adj service)).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
172 ((inventive adj problem adj solving) or (inventive adj problem-solving) or (inventive adj problemsolving) or (business adj process adj re-engineering) or (business adj process adj re-engineering)).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
173 (business adj process adj engineering).ti,ab.
174 (IHI or (Institute adj Healthcare adj Improvement)).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
175 (system* adj redesign).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
179 170 or 161 or 165 or 168 or 167 or 163 or 172 or 166 or 174 or 173 or 164 or 169 or 175 or 171
180 limit 179 to (english language and yr="2004 -Current")

NUMBER OF RESULTS: 696

CQI SEARCH #2:

176 ((process adj improvement) or (improvement adj collaborative*)).mp.
177 (advanced adj clinical adj access).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
178 cqi.ti,ab.
186 178 or 177 or 176
187 limit 186 to (english language and yr="2004 -Current")

NUMBER OF RESULTS: 203

ALL SEARCHES WERE COMBINED INTO ONE ENDNOTE FILE AND DUPLICATES WERE REMOVED. TOTAL NUMBER OF RESULTS IN COMBINED FILE: 9426 (9,395 after further duplicate removal based on the PubMed identifier)