# Analytic Framework Machine Learning in Systematic Reviews

Appendix Figure 1 Analytic Framework Machine Learning in Systematic Reviews

The analytic framework figure outlines the five stages of the project. It includes script roll pictures to represent the data (titles and abstracts of publications) and the decisions represented by an arrow pointing to the option “obtain full text” or an arrow pointing to the option “discard” for the first four stages. In the first stage, literature reviewers screen a sample of the search output and decide which titles and abstracts should be obtained and screened as full text and which should be discarded. In the second stage, the algorithm aims to learn and construct a model based on the reviewers’ decisions. In the third stage, the algorithm is applied to the entire search output to predict which titles and abstracts will be selected. In the fourth stage, the literature reviewers will sample the remaining titles and abstracts and inclusion screen these. In the final stage, the algorithm’s predictions are compared with the reviewers’ decisions. The last stage shows two tables, one for the algorithm’s predictions, one for the reviewer decisions; both show numbers representing citations and the example decision.