# References

1 Bucher HC, Guyatt GH, Griffith LE, et al. The results of direct and indirect treatment comparisons in meta-analysis of randomized controlled trials. J ClinEpidemiol. 1997;50:683-91. [pmid: 9250266].
2 Lumley T. Network meta-analysis for indirect treatment comparisons. Stats Med. 2002;21:2313-2324. [pmid: 12210616].
3 Fu R, Gartlehner G, Grant M, et al. Conducting Quantitative Synthesis When Comparing Medical Interventions: AHRQ and the Effective Health Care Program. Agency for Healthcare Research and Quality. Methods Guide for Comparative Effectiveness Reviews. [posted October 2010]. Rockville, MD. http://effectivehealthcare.ahrq.gov/. December 28, 2011.
4 Sutton A, Ades AE, Cooper N, et al. Use of indirect and mixed treatment comparisons for technology assessments. Pharmacoeconomics. 2008;26:753-767. [pmid: 18767896].
5 Lu G, Ades AE. Combination of direct and indirect evidence in mixed treatment comparisons. Stats Med. 2004;23:3105-3124. [pmid: 15449338].
6 Caldwell DM, Ades AE, Higgins PT. Simultaneous comparison of multiple treatments: combining direct and indirect evidence. BMJ. 2005;331:897-900. [pmid: 16223826].
7 Health Information and Quality Authority. Guidelines for Evaluating the Clinical Effectiveness of Health Technologies in Ireland. Dublin. Health Information and Quality Authority. 2011. Available at: http://www.hiqa.ie. December 28, 2011.
8 Glenny AM, Altman DG, Song F, et al. Indirect comparisons of competing interventions. Health Technol Assess. 2005;9(26). [pmid: 16014203].
9 Jansen JP, Fleurence R, Devine B, et al. Interpreting indirect treatment comparisons and network meta-analysis for health-care decision making: report of the ISPOR Task Force on Indirect Treatment Comparisons Good Research Practices: part 1. Value Health. 2011;14:417-28. [pmid: 21669366].
10 Hoaglin DC, Hawkins N, Jansen JP, et al. Conducting indirect-treatment-comparison and network-meta-analysis studies: report of the ISPOR Task Force on Indirect Treatment Comparisons Good Research Practices: part 2. Value Health. 2011;14:429-37. [pmid: 21669367].
11 Wells GA, Sultan SA, Chen L, et al. Indirect Evidence: Indirect Treatment Comparisons in Meta-Analysis. Ottawa. Canadian Agency for Drugs and Technologies in Health. 2009. www.cadth.ca. December 28, 2011.
12 Centre for Reviews and Dissemination. CRD's Guidance for Undertaking Reviews in Health Care. University of York. 2009. www.york.ac.uk/inst/crd/pdf/Systematic_Reviews.pdf. December 28, 2011.
13 Sung L, Hayden J, Greenberg ML, Koren G, Feldman BM, Tomlinson GA. Seven items were identified for inclusion when reporting a Bayesian analysis of a clinical study. J Clin Epidemiol. 2005;58:261-268. [pmid: 15718115].
14 Drug Effectiveness Review Project. Systematic Review Methods and Procedures. Portland, OR. 2011. www.ohsu.edu/xd/research/centers-institutes/evidence-based-policy-center/derp/documents/upload/DERP_METHODS_WEB_Final_January-201l-2.pdf. December 28, 2011.
15 Guidelines for the economic evaluation of health technologies: Canada. 3^rd^ Edition. Ottawa. Canadian Agency for Drugs and Technologies in Health. 2006. www.cadth.ca. December 28, 2011.
16 Li T, Puhan MA, Vedula SS, et al., Ad Hoc Network Meta-analysis Methods Meeting Working Group. Network meta-analysis-highly attractive but more methodological research is needed. BMC Med. 2011;9:79. [pmid: 21707969].
17 Pharmaceutical Benefits Advisory Committee. Guidelines for Preparing Submissions to the Pharmaceutical Benefits Advisory Committee (version 4.3). Australian Government, Department of health and Ageing. 2008. www.health.gov.au/internet/main/publishing.nsf/content/AECB791C29482920CA25724400188EDB/$File/PBAC4.3.2.pdf. December 28, 2011.
18 Report of the Indirect Comparisons Working Group (ICWG) to the Pharmaceutical Benefits Advisory Committee: Assessing Indirect Comparisons. Australian Government, Department of health and Ageing. Available at: www.health.gov.au/internet/main/publishing.nsf/Content/B11E8EF19B358E39CA25754B000A9C07/$File/ICWG%20Report%20FINAL2.pdf. December 28, 2011.
19 National Institute for Health and Clinical Excellence. Guide to the methods of technology appraisal. 2008. Available at: www.nice.org.uk. December 28, 2011.
20 National Institute for Health and Clinical Excellence (NICE). NICE Decision Support Unit Technical Support Documents for “Evidence Synthesis”. www.nicedsu.org.uk/Evidence-Synthesis-TSD-series%282391675%29.htm. June 10, 2012.
21 Cleemput I, Van Wilder P, Vrijens F, Huybrechts M, Ramaekers D. Guidelines for Pharmacoeconomic Evaluations in Belgium. Health Technology Assessment (HTA). Brussels. Health Care Knowledge Centre (KCE). 2008. KCE Reports 78C (D/2008/10.273/27). www.ispor.org/peguidelines/source/Belgium_Guidelines-for-Pharmacoeconomics-Evaluation-in-Belgium_2008_English.pdf. June 10, 2012.
22 German Institute for Quality and Efficiency in Health Care. Benefit Assessment of Pharmaceuticals pursuant to § 35a SGB V. 2008. Available at: www.english.g-ba.de/benefitassessment/information/. June 10, 2012.
23 Haute Autorite de Sante. Indirect comparisons Methods and validity. 2009. Available at: www.has-sante.fr/portail/upload/docs/application/pdf/2011-02/summary_report__indirect_comparisons_methods_and_validity_January_201l_2.pdf. June 10, 2012.
24 National Department of Health – Republic of South Africa. The Guidelines For Pharmacoeconomic Evaluations of Medicines and Scheduled Substances. 2010. Available at: www.ispor.org/PEguidelines/source/guidelines-for-pharmacoeconomic-evaluations-of-medicines-and-scheduled-substances_2010.pdf.
25 Higgins JPT, Green S, editors. Cochrane Handbook for Systematic Reviews of Interventions Version 5.1.0. [updated March 2011]. The Cochrane Collaboration. 2011. www.cochrane-handbook.org. December 28, 2011.
26 Evolution of Cochrane Intervention Reviews and Overviews of Reviews to better accommodate comparisons among multiple interventions. Report from a meeting of the Cochrane Comparing Multiple Interventions Methods Groups. Milan. March 2011. http://cmimg.cochrane.org/sites/cmimg.cochrane.org/files/uploads/CMIMG%20summary%20of%20meeting%20Milan%20March%202011.pdf. December 28, 2011.
27 Salanti G, Higgins JP, Ades AE, Ioannidis JP. Evaluation of networks of randomized trials. Stat Methods Med Res. 2008;17:279-301. [pmid: 17925316].
28 Viechtbauer W. Conducting meta-analyses in R with the metaphor package. J Stat Software. 2010;36:1-48.
29 Hawkins N, Scott DA, Woods B. How far do you go? Efficient searching for indirect evidence. Med Decis Making. 2009;29(3):273-81. [pmid: 19470721].
30 The BaSiS Group. Bayesian standards in science (BaSiS). http://lib.stat.cmu.edu/bayesworkshop/2001/BaSiS.html. September 21, 2011.
31 Spiegelhalter DJ, Myles JP, Jones DR, Abrams KR. Bayesian methods in health technology assessment: a review. Health Technol Assess. 2000;4:1-130. [pmid: 11134920].
32 Preferred reporting items for systematic reviews and meta-analyses. www.prisma-statement.org/statement.htm. April 4, 2012.
33 Bangalore S, Kumar S, Kjeldsen E, et al. Antihypertensive drugs and risk of cancer: network meta-analyses and trial sequential analysis of 324168 participants from randomized trials. Lancet Oncol. 2011;12:65-82. [pmid: 21123111].
34 Gross JL, Kramer CK, Leitao CB, et al. Effect of antihyperglycemics agents added to metformin and a sulfonylurea on glycemic control and weight gain in type 2 diabetes: a network meta-analysis. Ann Intern Med. 2011;154(10):672-679. [pmid: 21576535].
35 Hartling L, Fernandes RM, Bialy L, et al. Steroids and bronchodilators for acute bronchiolitis in the first two years of life: systematic review and meta-analysis. BMJ. 2011;342:1714. [pmid: 21471175].
36 Maund E, McDaid C, Rice S, Wright K, Jenkins B, Woolacott N. Paracetamol and selective and non-selective non-steroidal anti-inflammatory drugs for the reduction in morphine-related side-effects after major surgery: a systematic review. Br J Anaesth. 2011;106(3):292-297. [pmid: 21285082].
37 McDaid C, Maund E, Rice S, Wright K, Jenkins B, Woolacott N. Paracetamol and selective and non-selective non-steroidal anti-inflammatory drugs (NSAIDs) for the reduction of morphine-related side effects after major surgery: a systematic review. Health Technol Assess. 2010;14(17):1-153. [pmid: 20346263].
38 Sciarretta S, Palano F, Tocci G, Baldini R, Volpe M. Antihypertensive treatment and development of heart failure in hypertension: a Bayesian network meta-analysis of studies in patients with hypertension and high cardiovascular risk. Arch Intern Med. 2011;171(5):384-394. [pmid: 21059964].
39 Trelle S, Reichenback S, Wandel S, et al. Cardiovascular safety of non-steroidal anti-inflammatory drugs: network meta-analysis. BMJ. 2011;342:c7086. [pmid: 21224324].
40 van de Kerkhof P, de Peuter R, Ryttov J, Jansen JP. Mixed treatment comparison of a two-compound formulation (TCF) product containing calcipotriol and betamethasone dipropionate with other topical treatments in psoriasis vulgaris. Curr Med Res Opin. 2011;27(1):225-238. [pmid: 21142833].
41 Van den Bruel A, Gailly J, Devriese S, Welton NJ, Shortt AJ, Vrijens F. The protective effect of ophthalmic viscoelastic devices on endothelial cell loss during cataract surgery: a meta-analysis using mixed treatment comparisons. Br J Ophthalmol. 2011;95(1):5-10. [pmid: 19965836].
42 Dakin H, Fidler C, Harper C. Mixed treatment comparison meta-analysis evaluating the relative efficacy of nucleos(t)ides for treatment of nucleos(t)ide-naive patients with chronic hepatitis B. Value Health. 2010;13(8):934-945. [pmid: 20825624].
43 Orme M, Collins S, Dakin H, Kelly S, Loftus J. Mixed treatment comparison and meta-regression of the efficacy and safety of prostaglandin analogues and comparators for primary open-angle glaucoma and ocular hypertension. Curr Med Res Opin. 2010;26(3):511-528. [pmid: 20014995].
44 Phung OJ, Scholle JM, Talwar M, Coleman CI. Effect of noninsulin antidiabetic drugs added to metformin therapy on glycemic control, weight gain, and hypoglycemia in type 2 diabetes. JAMA. 2010;303(14):1410-1418. [pmid: 20388897].
45 Uthman OA, Abdulmalik J. Comparative efficacy and acceptability of pharmacotherapeutic agents for anxiety disorders in children and adolescents: a mixed treatment comparison meta-analysis. Curr Med Res Opin. 2010;26(1):53-59. [pmid: 19905879].
46 Vissers D, Stam W, Nolte T, Lenre M, Jansen J. Efficacy of intranasal fentanyl spray versus other opioids for breakthrough pain in cancer. Curr Med Res Opin. 2010;26(5):1037-1045. [pmid: 20199140].
47 Walsh T, Worthington HV, Glenny A, Appelbe P, Marinho CCV, Shi X. Fluoride toothpastes of different concentrations for preventing dental caries in children and adolescents. Cochrane Database of Systematic Reviews. 2011:1. Art No CD007868. [pmid: 20091655].
48 Wandel S, Juni P, Tendal B, Nuesch E, Villiger PM, Welton NJ, et al. Effects of glucosamine, chondroitin, or placebo in patients with osteoarthritis of hip or knee: network meta-analysis. BMJ. 2010;341:4675. [pmid: 20847017].
49 Wang H, Huang T, Jing J, Jin J, Wang P, Yang M, et al. Effectiveness of different central venous catheters for catheter-related infections: a network meta-analysis. J Hosp Infect. 2010;76(1):1-11. [pmid: 20638155].
50 Woo G, Tomlinson G, Nishikawa Y, Kowgier M, Sherman M, Wong DK, et al. Tenofovir and entecavir are the most effective antiviral agents for chronic hepatitis B: a systematic review and Bayesian meta-analyses. Gastroenterology. 2010;139(4):1218-1229. [pmid: 20600036].
51 Baker WL, Baker EL, Coleman CI. Pharmacologic treatments for chronic obstructive pulmonary disease: a mixed-treatment comparison meta-analysis. Pharmacotherapy. 2009;29(8):891-905. [pmid: 19637942].
52 Bansback N, Sizto S, Sun H, Feldman S, Willian MK, Anis A. Efficacy of systemic treatments for moderate to severe plaque psoriasis: systematic review and meta-analysis. Dermatology. 2009;219(3):209-218. [pmid: 19657180].
53 Cipriani A, Furukawa TA, Salanti G, Geddes JR, Higgins JP, Churchill R, et al. Comparative efficacy and acceptability of 12 new-generation antidepressants: a multiple-treatments meta-analysis. Lancet. 2009;373(9665):746-758. [pmid: 19185342].
54 Edwards SJ, Lind T, Lundell L, Das R. Systematic review: standard- and double-dose proton pump inhibitors for the healing of severe erosive oesophagitis – a mixed treatment comparison of randomized controlled trials. Aliment Pharmacol Ther. 2009;30(6):547-556. [pmid: 19558609].
55 Edwards SJ, Smith CJ. Tolerability of atypical antipsychotics in the treatment of adults with schizophrenia or bipolar disorder: a mixed treatment comparison of randomized controlled trials. Clin Ther. 2009;31(Pt 1):1345-1359. [pmid: 19698898].
56 Golfinopoulos V, Pentheroudakis G, Salanti G, Nearchou AD, Ioannidis JP, Pavlidis N. Comparative survival with diverse chemotherapy regimens for cancer of unknown primary site: multiple-treatments meta-analysis. Cancer Treat Rev. 2009;35(7):570-573. [pmid: 19539430].
57 ManzoliL Georgia S, De Vito C, Boccia A, Ionnidis JPA, Villari P. Immunogenicity and adverse events of avian influenza A H5N1 vaccine in healthy adults: multiple-treatments meta-analysis. Lancet Infect Dis. 2009;9:481-92. [pmid: 19628173].
58 Meader N. A comparison of methadone, buprenorphine and alpha2 adrenergic agonists for opiod detoxification: a mixed treatment comparison meta-analysis. Drug and Alcohol Dependence. 2010;108:110-114. [pmid: 20074867].
59 Coleman CI, Baker WL, Kluger J, White CM. Antihypertensive medication and their impact on cancer incidence: a mixed treatment comparison meta-analysis of randomized controlled trials. J Hypertens. 2008;26(4):622-629. [pmid: 18327066].
60 Mauri D, Polyzos NP, Salanti G, Pavlidis N, Ionnidis JPA. Multiple-treatments meta-analysis of chemotherapy and targeted therapies in advanced breast cancer. J Natl Cancer Inst. 2008;100:1780-1791. [pmid: 19066278].
61 Stettler C, Allemann S, Wandel S, et al. Drug eluting and bare metal stents in people with and without diabetes: collaborative network meta-analysis. BMJ. 2008;337:a1331. [pmid: 18757996].
62 Golfinopoulos V, Salanti G, Pavlidis N, Ioannidis JP. Survival and disease-progression benefits with treatment regimens for advanced colorectal cancer: a meta-analysis. Lancet Oncol. 2007;8(10):898-911. [pmid: 17888735].
63 Lam SK, Owen A. Combined resynchronisation and implantable defibrillator therapy in left ventricular dysfunction: Bayesian network meta-analysis of randomised controlled trials. BMJ. 2007;335(7626):925. [pmid: 17932160].
64 Nixon R, Bansback N, Brennan A. The efficacy of inhibiting tumour necrosis factor alpha and interleukin 1 in patients with rheumatoid arthritis: a meta-analysis and adjusted indirect comparisons. Rheumatology. 2007;46(7):1140-1147. [pmid: 17478472].
65 Cooper NJ, Sutton AJ, Lu G, Khunti K. Mixed comparison of stroke prevention treatments in individuals with nonrheumatic atrial fibrillation. Arch Intern Med. 2006;166(12):1269-1275. [pmid: 16801509].
66 Kyrgiou M, Salanti G, Pavlidis N, Paraskevaidis E, Ioannidis JP. Survival benefits with diverse chemotherapy regimens for ovarian cancer: meta-analysis of multiple treatments. J Natl Cancer Inst. 2006;98(22):1655-1663. [pmid: 17105988].
67 Baldwin D, Woods R, Lawson R, Taylor D. Efficacy of drug treatments for 45eneralized anxiety disorder: systematic review and meta-analysis. BMJ. 2011;342:1199. [pmid: 21398351].
68 Freemantle N, Lafuente-Lafuente C, Mitchell S, Eckert L, Reynolds M. Mixed treatment comparison of dronedarone, amiodarone, sotalol, flecainide, and propafenone, for the management of atrial fibrillation. Europace. 2011;13(3):329-345. [pmid: 21227948].
69 Anothaisintawee T, Attia J, Nickel JC, et al. Management of chronic prostatitis/chronic pelvic pain syndrome: a systematic review and network meta-analysis. JAMA. 2011;305(1):78-86. [pmid: 21205969].
70 Hansen RA, Gaynes BN, Gartlehner G, Moore CG, Tiwari R, Lohr KN. Efficacy and tolerability of second-generation antidepressants in social anxiety disorder. Int Clin Psychopharmacol. 2008;23(3):170-179. [pmid: 18408531].
71 Jalota L, Kalira V, George E, et al. Prevention of pain on injection of propofol: systematic review and meta-analysis. BMJ. 2011;342:1110. [pmid: 21406529].
72 Trikalinos TA, Alsheikh-Ali AA, Tatsioni A, Nallamothu BK, Kent DM. Percutaneous coronary interventions for non-acute coronary artery disease: a quantitative 20-year synopsis and a network meta-analysis. Lancet. 2009;373(9667):911-918. [pmid: 19286090].
73 Elliott WJ, Meyer PM. Incident diabetes in clinical trials of antihypertensive drugs: a network meta-analysis. Lancet. 2007;369(9557):201-207. [pmid: 17240286].
74 Singh JA, Wells GA, Christensen R, et al. Adverse effects of biologics: a network meta-analysis and Cochrane overview (review). Cochrane database of systematic reviews. 2011;(2). Art No. CD008794.
75 Roskell NS, Lip GYH, Noack H, Clemens A, Plumb JM. Treatments for stroke prevention in atrial fibrillation: a network meta-analysis and indirect comparison versus dabigatran etexilate. Thromb Haemost. 2010;104:1106-1115. [pmid: 20967400].
76 Eckert L, Lancon C. Duloextine compared with fluoxetine and venlafaxine: use of meta-regression analysis for indirect comparison. BMC Psychiatry. 2006;6:30. [pmid: 16867188].