# Peer Reviewers

Jeroen Jansen, Ph.D.

Mapi Consultancy

Boston, MA

Edward Mills, M.Sc., Ph.D., L.L.M.

Interdisciplinary School of Health Sciences

University of Ottawa

Ottawa, Canada

M. Hassan Murad, M.D.

Preventive, Occupational, and Aerospace

Medicine, Mayo Clinic

Rochester, MN

Christopher Schmid, Ph.D.

Biostatistics Research Center

Institute for Clinical Research and Health

Policy Studies, Tufts Medical Center

Professor of Medicine, Tufts University

Boston, MA

Nicky Welton, B.Sc., M.Sc., Ph.D.

School of Social and Community Medicine, University of Bristol

Bristol, United Kingdom