# Glossary

Closed loop network of evidence: A network of evidence where greater than two interventions are being compared indirectly, and at least one pair of interventions is being compared both directly and indirectly.
Lumley’s network meta-analysis approach: A Frequentist approach to conduct a MTC originally described by Lumley et al. whereby both direct and indirect evidence are combined when there is at least one closed loop of evidence connecting two interventions of interest using a mixed model
Meta-Analysis: The process of extracting and pooling data from several studies investigating a similar topic to synthesize a final outcome
Mixed treatment comparison (MTC): A statistical approach used to analyze a network of evidence with more than two interventions which are being compared indirectly, and at least one pair of interventions compared both directly and indirectly
Network meta-analysis: The simultaneous synthesis of evidence of all pairwise comparisons across more than two interventions
Markov chain Monte Carlo (MCMC) methods: Simulation-based methods which can be used for the analysis of complex statistical models and to obtain estimates from distributions.