# Excluded Studies

Table 4 Excluded studies at the full text level

Not a systematic review published in the English language from January 1, 2006 to July 30, 2011 (n=9)
Basu A, Meltzer HY, Dukic V. Estimating transitions between symptom severity states over time in schizophrenia: a Bayesian meta-analytic approach. Stat Med 2006 Sep 15;25(17):2886-2910.
Biondi-Zoccai GG, Lotrionte M, Abbate A, Valgimigli M, Testa L, Burzotta F, et al. Direct and indirect comparison meta-analysis demonstrates the superiority of sirolimus- versus paclitaxel-eluting stents across 5854 patients. Int J Cardiol 2007 Jan 2;114(1):104-105.
Biondi-Zoccai G, Lotrionte M, Moretti C, Agostoni P, Sillano D, Laudito A, et al. Percutaneous coronary intervention with everolimus-eluting stents (Xience V): systematic review and direct-indirect comparison meta-analyses with paclitaxel-eluting stents (Taxus) and sirolimus-eluting stents (Cypher). Minerva Cardioangiol 2008 Feb;56(1):55-65.
Buti J, Glenny AM, Worthington HV, Nieri M, Baccini M. Network meta-analysis of randomised controlled trials: direct and indirect treatment comparisons. Eur j oral implantol 2011;4(1):55-62.
Moayyedi P, Shelly S, Deeks JJ, Delaney B, Innes M, Forman D. Pharmacological interventions for non-ulcer dyspepsia. Cochrane Database of Systematic Reviews 2011;2.
Singh JA, Christensen R, Wells GA, Suarez-Almazor ME, Buchbinder R, Lopez-Olivo MA, et al. A network meta-analysis of randomized controlled trials of biologics for rheumatoid arthritis: a Cochrane overview. CMAJ 2009 Nov 24;181(11):787-796.
Trkulja V, Kolundzic R. Rivaroxaban vs dabigatran for thromboprophylaxis after joint-replacement surgery: exploratory indirect comparison based on meta-analysis of pivotal clinical trials. Croat Med J 2010 Apr 15;51(2):113-123.
Virgili G, Novielli N, Menchini F, Murro V, Giacomelli G. Pharmacological treatments for neovascular age-related macular degeneration: can mixed treatment comparison meta-analysis be useful? Curr Drug Targets 2011 Feb;12(2):212-220.
Wong MC, Clarkson J, Glenny AM, Lo EC, Marinho VC, Tsang BW, et al. Cochrane reviews on the benefits/risks of fluoride toothpastes. J Dent Res 2011 May;90(5):573-579.
Did not conduct meta-analysis of clinical effectiveness using randomized controlled trials (n=8)
Jefferson T, Di Pietrantonj C, AlAnsary LA, Ferroni E, Thorning S, Thomas RE. Vaccines for preventing influenza in the elderly. Cochrane Database of Systematic Reviews 2010;6.
Jefferson T, Rivetti A, Harnden A, Di Pietrantonj C, Demicheli V. Vaccines for preventing influenza in healthy children. Cochrane Database of Systematic Reviews 2009;1.
Medical Advisory Secretariat. Ontario Ministry of Health and Long-Term Care (MAS). Artificial disc replacement for lumbar and cervical degenerative disc disease-update: an evidence-based analysis (Structured abstract). Health Technology Assessment Database 2011 Issue 3, John Wiley & Sons, Ltd. Chichester:UK. Dson: ST.
Miller, J. Chan, BKS. Nelson, H. Hormone replacement therapy and risk of venous thromboembolism (Structured abstract). Health Technology Assessment Database 2011 Issue 3, John Wiley & Sons, Ltd. Chichester:UK. Dson: ST.
Paravastu SCV, Mendonca D, Da Silva A. Beta blockers for peripheral arterial disease. Cochrane Database of Systematic Reviews 2010;3.
Richy FF, Banerjee S, Brabant Y, Helmers S. Levetiracetam extended release and levetiracetam immediate release as adjunctive treatment for partial-onset seizures: an indirect comparison of treatment-emergent adverse events using meta-analytic techniques. Epilepsy Behav 2009 Oct;16(2):240-245.
Takeda AL, Colquitt J, Clegg AJ, Jones J. Pegaptanib and ranibizumab for neovascular age-related macular degeneration: a systematic review. Br J Ophthalmol 2007 Sep;91(9):1177-1182.
van Till JO, van Ruler O, Lamme B, Weber RJ, Reitsma JB, Boermeester MA. Single-drug therapy or selective decontamination of the digestive tract as antifungal prophylaxis in critically ill patients: a systematic review. Crit Care 2007;11(6):R126.
Did not conduct an indirect comparison of more than two arms (n=113)
Abba K, Ramaratnam S, Ranganathan NL. Anthelmintics for people with neurocysticercosis. Cochrane Database of Systematic Reviews 2010;6.
Avenell A, Gillespie WJ, Gillespie LD, O'Connell D. Vitamin D and vitamin D analogues for preventing fractures associated with involutional and post-menopausal osteoporosis. Cochrane Database of Systematic Reviews 2009;1.
BlueCross BlueShield A. Metal-on-metal total hip resurfacing (Structured abstract). Health Technology Assessment Database 2011 Issue 3, John Wiley & Sons, Ltd. Chichester:UK. Dson: ST.
Bohlius J, Herbst C, Reiser M, Schwarzer G, Engert A. Granulopoiesis-stimulating factors to prevent adverse effects in the treatment of malignant lymphoma. Cochrane Database of Systematic Reviews 2009;1.
Bolen S, Feldman L, Vassy J, Wilson L, Yeh HC, Marinopoulos S, et al. Systematic review: comparative effectiveness and safety of oral medications for type 2 diabetes mellitus. Ann Intern Med 2007 Sep 18;147(6):386-399.
Brownfoot FC, Crowther CA, Middleton P. Different corticosteroids and regimens for accelerating fetal lung maturation for women at risk of preterm birth. Cochrane Database of Systematic Reviews 2009;1.
Brozek J, Akl EA, Jaeschke R, Terrenato I, Cilenti V, Cazzola M, et al. Long-acting beta2-agonists for chronic obstructive pulmonary disease: serious adverse events. Cochrane Database of Systematic Reviews 2009;1.
Bunn F, Trivedi D, Ashraf S. Colloid solutions for fluid resuscitation. Cochrane Database of Systematic Reviews 2011;5.
Cahill K, Lancaster T, Green N. Stage-based interventions for smoking cessation. Cochrane Database of Systematic Reviews 2011;1.
Caldwell D, Hunot V, Moore HMT, Davies P, Jones H, Lewis G, et al. Behavioural therapies versus treatment as usual for depression. Cochrane Database of Systematic Reviews 2010;6.
Castells X, RamosQuiroga AJ, Bosch R, Nogueira M, Casas M. Amphetamines for Attention Deficit Hyperactivity Disorder (ADHD) in adults. Cochrane Database of Systematic Reviews 2011;4.
Chandrasekaran B, Arumugam A, Davis F, Kumaran D S, Chandrasharma B, Khundrakpam C, et al. Resistance exercise training for hypertension. Cochrane Database of Systematic Reviews 2010;11.
Churchill R, Caldwell D, Moore HMT, Davies P, Jones H, Lewis G, et al. Behavioural therapies versus other psychological therapies for depression. Cochrane Database of Systematic Reviews 2010;6.
Churchill R, Davies P, Caldwell D, Moore HMT, Jones H, Lewis G, et al. Interpersonal, cognitive analytic and other integrative therapies versus treatment as usual for depression. Cochrane Database of Systematic Reviews 2010;6.
Churchill R, Davies P, Caldwell D, Moore HMT, Jones H, Lewis G, et al. Humanistic therapies versus other psychological therapies for depression. Cochrane Database of Systematic Reviews 2010;6.
Churchill R, Moore HMT, Caldwell D, Davies P, Jones H, Furukawa TA, et al. Cognitive behavioural therapies versus other psychological therapies for depression. Cochrane Database of Systematic Reviews 2010;6.
Churchill R, Moore HMT, Davies P, Caldwell D, Jones H, Lewis G, et al. Psychodynamic therapies versus other psychological therapies for depression. Cochrane Database of Systematic Reviews 2010;6.
Churchill R, Moore HMT, Davies P, Caldwell D, Jones H, Lewis G, et al. Mindfulness-based ‘third wave’ cognitive and behavioural therapies versus treatment as usual for depression. Cochrane Database of Systematic Reviews 2010;6.
Cipriani A, La Ferla T, Furukawa TA, Signoretti A, Nakagawa A, Churchill R, et al. Sertraline versus other antidepressive agents for depression. Cochrane Database of Systematic Reviews 2011;2.
Cipriani A, Santilli C, Furukawa TA, Signoretti A, Nakagawa A, McGuire H, et al. Escitalopram versus other antidepressive agents for depression. Cochrane Database of Systematic Reviews 2009;1.
Clarkson JE, Worthington HV, Eden TOB. Interventions for preventing oral candidiasis for patients with cancer receiving treatment. Cochrane Database of Systematic Reviews 2009;1.
Coppin C, Porzsolt F, Autenrieth M, Kumpf J, Coldman A, Wilt T. Immunotherapy for advanced renal cell cancer. Cochrane Database of Systematic Reviews 2009;1.
Cross NB, Webster AC, Masson P, O'Connell PJ, Craig JC. Antihypertensive treatment for kidney transplant recipients. Cochrane Database of Systematic Reviews 2010;2.
Davies P, Hunot V, Moore HMT, Caldwell D, Jones H, Lewis G, et al. Humanistic therapies versus treatment as usual for depression. Cochrane Database of Systematic Reviews 2010;6.
de Peuter OR, Lussana F, Peters RJ, Buller HR, Kamphuisen PW. A systematic review of selective and non-selective beta blockers for prevention of vascular events in patients with acute coronary syndrome or heart failure. Neth J Med 2009 Oct;67(9):284-294.
Deacon SA, Glenny A, Deery C, Robinson PG, Heanue M, Walmsley DA, et al. Different powered toothbrushes for plaque control and gingival health. Cochrane Database of Systematic Reviews 2011;4.
Delahoy P, Thompson S, Marschner IC. Pregabalin versus gabapentin in partial epilepsy: a meta-analysis of dose-response relationships. BMC Neurol 2010;10:104.
Derry S, Faura C, Edwards J, McQuay HJ, Moore AR. Single dose dipyrone for acute postoperative pain. Cochrane Database of Systematic Reviews 2011;5.
Derry S, Moore AR, McQuay HJ. Single dose oral codeine, as a single agent, for acute postoperative pain in adults. Cochrane Database of Systematic Reviews 2010;8.
Di Nisio M, Wichers IM, Middeldorp S. Treatment for superficial thrombophlebitis of the leg. Cochrane Database of Systematic Reviews 2011;2.
Eisenberg MJ, Filion KB, Yavin D, Belisle P, Mottillo S, Joseph L, et al. Pharmacotherapies for smoking cessation: a meta-analysis of randomized controlled trials. CMAJ 2008 Jul 15;179(2): 135-144.
Faraone SV, Glatt SJ. A comparison of the efficacy of medications for adult attention-deficit/hyperactivity disorder using meta-analysis of effect sizes. J Clin Psychiatry 2010 Jun;71(6):754-763.
Farion KJ, Russell KF, Osmond MH, Hartling L, Klassen TP, Durec T, et al. Tissue adhesives for traumatic lacerations in children and adults. Cochrane Database of Systematic Reviews 2011;4.
Filion KB, El Khoury F, Bielinski M, Schiller I, Dendukuri N, Brophy JM. Omega-3 fatty acids in high-risk cardiovascular patients: a meta-analysis of randomized controlled trials. BMC Cardiovasc Disord 2010;10:24.
Galaal K, Godfrey K, Naik R, Kucukmetin A, Bryant A. Adjuvant radiotherapy and/or chemotherapy after surgery for uterine carcinosarcoma. Cochrane Database of Systematic Reviews 2011;4.
Gartlehner G, Gaynes BN, Hansen RA, Thieda P, DeVeaugh-Geiss A, Krebs EE, et al. Comparative benefits and harms of second-generation antidepressants: background paper for the American College of Physicians. Ann Intern Med 2008 Nov 18;149(10):734-750.
Gillespie LD, Robertson CM, Gillespie WJ, Lamb SE, Gates S, Cumming RG, et al. Interventions for preventing falls in older people living in the community. Cochrane Database of Systematic Reviews 2010;10.
Gotzsche PC, Johansen HK. House dust mite control measures for asthma. Cochrane Database of Systematic Reviews 2009;1.
Guaiana G, Barbui C, Cipriani A. Hydroxyzine for generalised anxiety disorder. Cochrane Database of Systematic Reviews 2009;1.
Gurusamy KS, Kumar Y, Davidson BR. Methods of preventing bacterial sepsis and wound complications for liver transplantation. Cochrane Database of Systematic Reviews 2009;1.
Henry DA, Carless PA, Moxey AJ, O'Connell D, Stokes BJ, Fergusson DA, et al. Anti-fibrinolytic use for minimising perioperative allogeneic blood transfusion. Cochrane Database of Systematic Reviews 2011;5.
Hodson EM, Craig JC, Strippoli FMG, Webster AC. Antiviral medications for preventing cytomegalovirus disease in solid organ transplant recipients. Cochrane Database of Systematic Reviews 2010;4.
Hooper L, Summerbell CD, Thompson R, Sills D, Roberts FG, Moore H, et al. Reduced or modified dietary fat for preventing cardiovascular disease. Cochrane Database of Systematic Reviews 2011;7.
Hunot V, Moore HMT, Caldwell D, Davies P, Jones H, Furukawa TA, et al. Cognitive behavioural therapies versus treatment as usual for depression. Cochrane Database of Systematic Reviews 2010;6.
Hunot V, Moore HMT, Caldwell D, Davies P, Jones H, Lewis G, et al. Mindfulness-based ‘third wave’ cognitive and behavioural therapies versus other psychological therapies for depression. Cochrane Database of Systematic Reviews 2010;6.
Hunot V, Moore HMT, Caldwell D, Davies P, Jones H, Lewis G, et al. Interpersonal, cognitive analytic and other integrative therapies versus other psychological therapies for depression. Cochrane Database of Systematic Reviews 2010;6.
Iorio A, Marchesini E, Awad T, Gluud LL. Antiviral treatment for chronic hepatitis C in patients with human immunodeficiency virus. Cochrane Database of Systematic Reviews 2010;5.
Ipser JC, Stein DJ, Hawkridge S, Hoppe L. Pharmacotherapy for anxiety disorders in children and adolescents. Cochrane Database of Systematic Reviews 2010;6.
Itchaki G, GafterGvili A, Lahav M, Vidal L, Raanani P, Shpilberg O, et al. Anthracyclines-containing regimens for treatment of follicular lymphoma in adults. Cochrane Database of Systematic Reviews 2010;8.
Jackson PPR, Aarabi M, Wallis E. Aspirin for primary prevention of coronary heart disease. Cochrane Database of Systematic Reviews 2009;1.
Jefferson T, Jones MA, Doshi P, Del Mar CB, Heneghan CJ, Hama R, et al. Neuraminidase inhibitors for preventing and treating influenza in healthy adults and children - a review of clinical study reports. Cochrane Database of Systematic Reviews 2011;4.
Johansson K, Sundstrom J, Neovius K, Rossner S, Neovius M. Long-term changes in blood pressure following orlistat and sibutramine treatment: a meta-analysis. Obes Rev 2010 Nov;11(11):777-791.
Kaizar EE, Greenhouse JB, Seltman H, Kelleher K. Do antidepressants cause suicidality in children? A Bayesian meta-analysis. Clin trials 2006 discussion 91-8;3(2):73-90.
Kamphuisen PW, Agnelli G. What is the optimal pharmacological prophylaxis for the prevention of deep-vein thrombosis and pulmonary embolism in patients with acute ischemic stroke? Thromb Res 2007;119(3):265-274.
Kulisevsky J, Pagonabarraga J. Tolerability and safety of ropinirole versus other dopamine agonists and levodopa in the treatment of Parkinson's disease: meta-analysis of randomized controlled trials. Drug Saf 2010 Feb 1;33(2):147-161.
Lancaster T, Stead LF. Individual behavioural counselling for smoking cessation. Cochrane Database of Systematic Reviews 2009;1.
Law S, Derry S, Moore AR. Triptans for acute cluster headache. Cochrane Database of Systematic Reviews 2011;1.
Lin Y, Stanworth S, Birchall J, Doree C, Hyde C. Recombinant factor VIIa for the prevention and treatment of bleeding in patients without haemophilia. Cochrane Database of Systematic Reviews 2011;4.
Logman JF, Stephens J, Heeg B, Haider S, Cappelleri J, Nathwani D, et al. Comparative effectiveness of antibiotics for the treatment of MRSA complicated skin and soft tissue infections. Curr Med Res Opin 2010 Jul;26(7):1565-1578.
Maas T, Kaper J, Sheikh A, Knottnerus JA, Wesseling G, Dompeling E, et al. Mono and multifaceted inhalant and/or food allergen reduction interventions for preventing asthma in children at high risk of developing asthma. Cochrane Database Syst Rev 2009(3):006480.
Maas T, Kaper J, Sheikh A, Knottnerus AJ, Wesseling G, Dompeling E, et al. Mono and multifaceted inhalant and/or food allergen reduction interventions for preventing asthma in children at high risk of developing asthma. Cochrane Database of Systematic Reviews 2011;4.
Manheimer E, Cheng K, Linde K, Lao L, Yoo J, Wieland S, et al. Acupuncture for peripheral joint osteoarthritis. Cochrane Database of Systematic Reviews 2010;5.
Massey T, Derry S, Moore AR, McQuay HJ. Topical NSAIDs for acute pain in adults. Cochrane Database of Systematic Reviews 2010;6.
McQuay HJ, Moore RA. Dose-response in direct comparisons of different doses of aspirin, ibuprofen and paracetamol (acetaminophen) in analgesic studies. Br J Clin Pharmacol 2007 Mar;63(3):271-278.
Moore HMT, Hunot V, Davies P, Caldwell D, Jones H, Lewis G, et al. Psychodynamic therapies versus treatment as usual for depression. Cochrane Database of Systematic Reviews 2010;6.
Mottillo S, Filion KB, Belisle P, Joseph L, Gervais A, O'Loughlin J, et al. Behavioural interventions for smoking cessation: a meta-analysis of randomized controlled trials. Eur Heart J 2009 Mar;30(6):718-730.
Nakagawa A, Watanabe N, Omori IM, Barbui C, Cipriani A, McGuire H, et al. Milnacipran versus other antidepressive agents for depression. Cochrane Database of Systematic Reviews 2009; 1.
Nguyen ND, Eisman JA, Nguyen TV. Anti-hip fracture efficacy of biophosphonates: a Bayesian analysis of clinical trials. J Bone Miner Res 2006 Feb;21(2):340-349.
Omori IM, Watanabe N, Nakagawa A, Cipriani A, Barbui C, McGuire H, et al. Fluvoxamine versus other anti-depressive agents for depression. Cochrane Database of Systematic Reviews 2010;6.
Pavlakis N, Schmidt RL, Stockler MR. Bisphosphonates for breast cancer. Cochrane Database of Systematic Reviews 2009; 1.
Pepas L, Kaushik S, Bryant A, Nordin A, Dickinson HO. Medical interventions for high grade vulval intraepithelial neoplasia. Cochrane Database of Systematic Reviews 2011;4.
Perletti G, Marras E, Wagenlehner MEF, Magri V. Antimicrobial therapy for chronic bacterial prostatitis. Cochrane Database of Systematic Reviews 2011;5.
Phillips RS, Gopaul S, Gibson F, Houghton E, Craig JV, Light K, et al. Antiemetic medication for prevention and treatment of chemotherapy induced nausea and vomiting in childhood. Cochrane Database of Systematic Reviews 2011;2.
Piscione F, Piccolo R, Cassese S, Galasso G, De Rosa R, D'Andrea C, et al. Effect of drug-eluting stents in patients with acute ST-segment elevation myocardial infarction undergoing percutaneous coronary intervention: a meta-analysis of randomised trials and an adjusted indirect comparison. EuroIntervention 2010 Feb;5(7):853-860.
Playford EG, Webster AC, Sorrell TC, Craig JC. Systematic review and meta-analysis of antifungal agents for preventing fungal infections in liver transplant recipients. Eur J Clin Microbiol Infect Dis 2006 Sep;25(9):549-561.
Rada G, Capurro D, Pantoja T, Corbalan J, Moreno G, Letelier LM, et al. Non-hormonal interventions for hot flushes in women with a history of breast cancer. Cochrane Database of Systematic Reviews 2010;8.
Rayner L, Price A, Evans A, Valsraj K, Higginson IJ, Hotopf M. Antidepressants for depression in physically ill people. Cochrane Database of Systematic Reviews 2010;6.
Razavian M, Di Micco L, Palmer SC, Craig JC, Perkovic V, Zoungas S, et al. Antiplatelet agents for chronic kidney disease. Cochrane Database of Systematic Reviews 2010;11.
Reinhart M, Musini VM, Salzwedel DM, Dormuth C, Wright JM. First-line diuretics versus other classes of antihypertensive drugs for hypertension. Cochrane Database of Systematic Reviews 2011;4.
Reveiz L, Cardona FA, Ospina GE. Antibiotics for acute laryngitis in adults. Cochrane Database of Systematic Reviews 2011;5.
Rigotti N, Munafo' MR, Stead LF. Interventions for smoking cessation in hospitalised patients. Cochrane Database of Systematic Reviews 2009;1.
Rossi A, Garassino MC, Cinquini M, Sburlati P, Di Maio M, Farina G, et al. Maintenance or consolidation therapy in small-cell lung cancer: a systematic review and meta-analysis. Lung Cancer 2010 Nov;70(2):119-128.
Rowe BH, Spooner C, Ducharme F, Bretzlaff J, Bota G. Corticosteroids for preventing relapse following acute exacerbations of asthma. Cochrane Database of Systematic Reviews 2009;1.
Sandercock AGP, Counsell C, Kamal AK. Anticoagulants for acute ischaemic stroke. Cochrane Database of Systematic Reviews 2010;8.
Sandercock AGP, Gibson LM, Liu M. Anticoagulants for preventing recurrence following presumed non-cardioembolic ischaemic stroke or transient ischaemic attack. Cochrane Database of Systematic Reviews 2010;10.
Sandercock PAG, Counsell C, Gubitz GJ, Tseng M. Antiplatelet therapy for acute ischaemic stroke. Cochrane Database of Systematic Reviews 2009;1.
Sasse EC, Sasse AD, Brandalise SR, Clark OAC, Richards S. Colony-stimulating factors for prevention of myelosuppressive therapy-induced febrile neutropenia in children with acute lymphoblastic leukaemia. Cochrane Database of Systematic Reviews 2009;1.
Scholz H, Trenkwalder C, Kohnen R, Kriston L, Riemann D, Hornyak M. Dopamine agonists for the treatment of restless legs syndrome. Cochrane Database of Systematic Reviews 2011;5.
Shanbhag S, Cairns M, Cruickshank M, Dickinson HO, Gokul S, Parkin D. Effectiveness of different treatment modalities for the management of adult onset granulosa cell tumours of the ovary (primary and recurrent). Cochrane Database of Systematic Reviews 2009;1.
Siegfried N, van der Merwe L, Brocklehurst P, Sint TT. Antiretrovirals for reducing the risk of mother-to-child transmission of HIV infection. Cochrane Database of Systematic Reviews 2011;7.
Simpson SA, Lewis R, van der Voort J, Butler CC. Oral or topical nasal steroids for hearing loss associated with otitis media with effusion in children. Cochrane Database of Systematic Reviews 2011;5.
Small LN, Lau J, Snydman DR. Preventing post-organ transplantation cytomegalovirus disease with ganciclovir: a meta-analysis comparing prophylactic and preemptive therapies. Clin Infect Dis 2006 Oct 1;43(7):869-880.
Solomon R, Dumouchel W. Contrast media and nephropathy: findings from systematic analysis and Food and Drug Administration reports of adverse effects. Invest Radiol 2006 Aug;41(8):651-660.
Soomro GM, Altman DG, Rajagopal S, Oakley Browne M. Selective serotonin re-uptake inhibitors (SSRIs) versus placebo for obsessive compulsive disorder (OCD). Cochrane Database of Systematic Reviews 2009;1.
Spaulding A, Rutherford GW, Siegfried N. Stavudine or zidovudine in three-drug combination therapy for initial treatment of HIV infection in antiretroviral-naive individuals. Cochrane Database of Systematic Reviews 2011;4.
Stowe R, Ives N, Clarke CE, Deane K, van H, Wheatley K, et al. Evaluation of the efficacy and safety of adjuvant treatment to levodopa therapy in Parkinson s disease patients with motor complications. Cochrane Database Syst Rev 2010(7):007166.
Stowe R, Ives N, Clarke CE, van Hilten, Ferreira J, Hawker RJ, et al. Dopamine agonist therapy in early Parkinson's disease. Cochrane Database of Systematic Reviews 2011;1.
Strassels S, McNicol ED, Francia M, Belle D, Pepin J, Jackson KC. Meperidine (pethidine) for treatment of postoperative pain in adults. Cochrane Database of Systematic Reviews 2009;1.
Strippoli FMG, Bonifati C, Craig ME, Navaneethan SD, Craig JC. Angiotensin converting enzyme inhibitors and angiotensin II receptor antagonists for preventing the progression of diabetic kidney disease. Cochrane Database of Systematic Reviews 2011;1.
Sudlow CLM, Mason G, Maurice JB, Wedderburn CJ, Hankey GJ. Thienopyridine derivatives versus aspirin for preventing stroke and other serious vascular events in high vascular risk patients. Cochrane Database of Systematic Reviews 2010;2.
Tacklind J, Fink HA, MacDonald R, Rutks I, Wilt TJ. Finasteride for benign prostatic hyperplasia. Cochrane Database of Systematic Reviews 2011;2.
Tan A, Xia N, Gao F, Mo Z, Cao Y. Angiogenesis-inhibitors for metastatic thyroid cancer. Cochrane Database of Systematic Reviews 2010;6.
Tang W, Wong GWK, Perez MI, Wright JM. First-line drugs inhibiting the renin angiotensin system versus other first-line antihypertensive drug classes for hypertension. Cochrane Database of Systematic Reviews 2009;1.
Thomas RE, Russell M, Lorenzetti D. Interventions to increase influenza vaccination rates of those 60 years and older in the community. Cochrane Database of Systematic Reviews 2011;7.
Thomsen T, Villebro N, Moller AM. Interventions for preoperative smoking cessation. Cochrane Database Syst Rev 2010(7):002294.
Vardi M, Jacobson E, Nini A, Bitterman H. Intermediate acting versus long acting insulin for type 1 diabetes mellitus. Cochrane Database of Systematic Reviews 2011;1.
Vardi M, Zittan E, Bitterman H. Subcutaneous unfractionated heparin for the initial treatment of venous thromboembolism. Cochrane Database of Systematic Reviews 2010;2.
Visser K, van der Heijde D. Optimal dosage and route of administration of methotrexate in rheumatoid arthritis: a systematic review of the literature. Ann Rheum Dis 2009 Jul;68(7):1094-1099.
Wardlaw JM, Murray V, Berge E, del Zoppo GJ. Thrombolysis for acute ischaemic stroke. Cochrane Database of Systematic Reviews 2010;2.
Watanabe N, Churchill R, Hunot V, Furukawa TA. Psychotherapy for depression in children and adolescents. Cochrane Database of Systematic Reviews 2009;1.
Webster AC, Lee VWS, Chapman JR, Craig JC. Target of rapamycin inhibitors (TOR-I; sirolimus and everolimus) for primary immunosuppression in kidney transplant recipients. Cochrane Database of Systematic Reviews 2009;1.
Webster AC, Ruster LP, McGee R, Matheson SL, Higgins GY, Willis NS, et al. Interleukin 2 receptor antagonists for kidney transplant recipients. Cochrane Database of Systematic Reviews 2010;5.
Yuan Y, Ford AC, Khan KJ, Forman D, Oderda G, Calvet X, et al. Optimum duration of regimens for Helicobacter pylori eradication. Cochrane Database of Systematic Reviews 2009;1.
Did not use either Bayesian or Frequentist mixed treatment comparison method (n=41)
Abdullah AK, Khan S. Relative oral corticosteroid-sparing effect of 7 inhaled corticosteroids in chronic asthma: a meta-analysis. Ann Allergy Asthma Immunol 2008 Jul;101(1):74-81.
Abou-Setta AM. Firm embryo transfer catheters for assisted reproduction: a systematic review and meta-analysis using direct and adjusted indirect comparisons. Reprod Biomed Online 2006 Feb;12(2):191-198.
Abou-Setta AM. What is the best site for embryo deposition? A systematic review and meta-analysis using direct and adjusted indirect comparisons. Reprod Biomed Online 2007 May;14(5):611-619.
Berner MM, Kriston L, Harms A. Efficacy of PDE-5-inhibitors for erectile dysfunction. A comparative meta-analysis of fixed-dose regimen randomized controlled trials administering the International Index of Erectile Function in broad-spectrum populations. Int J Impot Res 2006 May-Jun;18(3):229-235.
Bottomley JM, Taylor RS, Ryttov J. The effectiveness of two-compound formulation calcipotriol and betamethasone dipropionate gel in the treatment of moderately severe scalp psoriasis: a systematic review of direct and indirect evidence. Curr Med Res Opin 2011 Jan;27(1):251-268.
Buscemi N, Vandermeer B, Friesen C, Bialy L, Tubman M, Ospina M, et al. The efficacy and safety of drug treatments for chronic insomnia in adults: a meta-analysis of RCTs. J Gen Intern Med 2007 Sep;22(9):1335-1350.
Chen MHJ, Heran BS, Perez MI, Wright JM. Blood pressure lowering efficacy of beta-blockers as second-line therapy for primary hypertension. Cochrane Database of Systematic Reviews 2010;5.
Chen JMH, Heran BS, Wright JM. Blood pressure lowering efficacy of diuretics as second-line therapy for primary hypertension. Cochrane Database of Systematic Reviews 2010;2.
Chou R, Carson S, Chan BK. Gabapentin versus tricyclic antidepressants for diabetic neuropathy and post-herpetic neuralgia: discrepancies between direct and indirect meta-analyses of randomized controlled trials. J Gen Intern Med 2009 Feb;24(2):178-188.
Fakhoury W, Lockhart I, Kotchie RW, Aagren M, LeReun C. Indirect comparison of once daily insulin detemir and glargine in reducing weight gain and hypoglycaemic episodes when administered in addition to conventional oral anti-diabetic therapy in patients with type-2 diabetes. Pharmacology 2008;82(2):156-163.
Gartlehner G, Hansen RA, Jonas BL, Thieda P, Lohr KN. The comparative efficacy and safety of biologics for the treatment of rheumatoid arthritis: a systematic review and metaanalysis. J Rheumatol 2006 Dec;33(12):2398-2408.
Germani G, Pleguezuelo M, Gurusamy K, Meyer T, Isgro G, Burroughs AK. Clinical outcomes of radiofrequency ablation, percutaneous alcohol and acetic acid injection for 6epatocellular carcinoma: a meta-analysis. J Hepatol 2010 Mar;52(3):380-388.
Hansen RA, Gartlehner G, Webb AP, Morgan LC, Moore CG, Jonas DE. Efficacy and safety of donepezil, galantamine, and rivastigmine for the treatment of Alzheimer's disease: a systematic review and meta-analysis. Clin Interv Aging 2008;3(2):211-225.
Hauser W, Petzke F, Sommer C. Comparative efficacy and harms of duloxetine, milnacipran, and pregabalin in fibromyalgia syndrome. J Pain 2010 Jun;11(6):505-521.
Heran BS, Chen MHJ, Wang JJ, Wright JM. Blood pressure lowering efficacy of potassium-sparing diuretics (that block the epithelial sodium channel) for primary hypertension. Cochrane Database of Systematic Reviews 2010;5.
Heran BS, Galm BP, Wright JM. Blood pressure lowering efficacy of alpha blockers for primary hypertension. Cochrane Database of Systematic Reviews 2010;2.
Heran BS, Wong MMY, Heran IK, Wright JM. Blood pressure lowering efficacy of angiotensin converting enzyme (ACE) inhibitors for primary hypertension. Cochrane Database of Systematic Reviews 2009;1.
Heran BS, Wong MMY, Heran IK, Wright JM. Blood pressure lowering efficacy of angiotensin receptor blockers for primary hypertension. Cochrane Database of Systematic Reviews 2009;1.
Hofmeyr GJ, Gulmezoglu AM, Novikova N, Linder V, Ferreira S, Piaggio G. Misoprostol to prevent and treat postpartum haemorrhage: a systematic review and meta-analysis of maternal deaths and dose-related effects. Bull World Health Organ 2009 Sep;87(9):666-677.
Holley A, King C, Moores L, Jackson JL, Shorr A. The role of twice versus three times daily heparin dosing for thromboembolism prophylaxis in general medical patients admitted to the hospital. Cochrane Database of Systematic Reviews 2009;1.
Jalota L, Kalira V, George E, et al. Prevention of pain on injection of propofol: systematic review and meta-analysis. BMJ 2011;342:1110.
Kabra SK, Lodha R, Pandey RM. Antibiotics for community-acquired pneumonia in children. Cochrane Database of Systematic Reviews 2010;6.
Kalil AC, Mindru C, Florescu DF. Effectiveness of valganciclovir 900 mg versus 450 mg for cytomegalovirus prophylaxis in transplantation: direct and indirect treatment comparison meta-analysis. Clin Infect Dis 2011 Feb;52(3):313-321.
Kotze A, Scally A, Howell S. Efficacy and safety of different techniques of paravertebral block for analgesia after thoracotomy: a systematic review and metaregression. Br J Anaesth 2009 Nov;103(5):626-636.
Kumar S, Ahuja V, Vishnubhatla S, Prasad K, Kumar A. Curcumin for maintenance of remission in ulcerative colitis. Cochrane Database of Systematic Reviews 2011;2.
Kumar A, Hozo I, Wheatley K, Djulbegovic B. Thalidomide versus bortezomib based regimens as first-line therapy for patients with multiple myeloma: a systematic review. Am J Hematol 2011 Jan;86(1):18-24.
Latthe PM, Singh P, Foon R, Toozs-Hobson P. Two routes of transobturator tape procedures in stress urinary incontinence: a meta-analysis with direct and indirect comparison of randomized trials. BJU Int 2010 Jul;106(1):68-76.
Lim E, Harris G, Patel A, Adachi I, Edmonds L, Song F. Preoperative versus postoperative chemotherapy in patients with resectable non-small cell lung cancer: systematic review and indirect comparison meta-analysis of randomized trials. J Thorac Oncol 2009 Nov;4(11):1380-1388.
Lim E, Harris G, Patel A, Adachi I, Edmonds L, Song F. Preoperative versus postoperative chemotherapy in patients with resectable non-small cell lung cancer: Systematic review and indirect comparison meta-analysis of randomized trials [abstract no.7546]. Journal of Clinical Oncology: ASCO annual meeting proceedings 2008;26(15S part I):408.
Loke YK, Kwok CS. Dabigatran and rivaroxaban for prevention of venous thromboembolism—systematic review and adjusted indirect comparison. J Clin Pharm Ther 2011 Feb;36(1):111-124.
Mills EJ, Rachlis B, O'Regan C, Thabane L, Perri D. Metastatic renal cell cancer treatments: an indirect comparison meta-analysis. BMC Cancer 2009;9:34.
Peterson K, McDonagh MS, Fu R. Comparative benefits and harms of competing medications for adults with attention-deficit hyperactivity disorder: a systematic review and indirect comparison meta-analysis. Psychopharmacology (Berl) 2008 Mar; 197(1):1-11.
Piccini JP, Hasselblad V, Peterson ED, Washam JB, Califf RM, Kong DF. Comparative efficacy of dronedarone and amiodarone for the maintenance of sinus rhythm in patients with atrial fibrillation. J Am Coll Cardiol 2009 Sep 15;54(12):1089-1095.
Riemsma R, Forbes CA, Kessels A, Lykopoulos K, Amonkar MM, Rea DW, et al. Systematic review of aromatase inhibitors in the first-line treatment for hormone sensitive advanced or metastatic breast cancer. Breast Cancer Res Treat 2010 Aug;123(1):9-24.
Riemsma R, Simons JP, Bashir Z, Gooch CL, Kleijnen J. Systematic Review of topotecan (Hycamtin) in relapsed small cell lung cancer. BMC Cancer 2010;10:436.
Rostom A, Dube C, Jolicoeur E, Joyce JL, Muir K. Adverse gastrointestinal effects of COX-2 Inhibitors for inflammatory diseases. Cochrane Database of Systematic Reviews 2009;1.
Salliot C, Finckh A, Katchamart W, Lu Y, Sun Y, Bombardier C, et al. Indirect comparisons of the efficacy of biological antirheumatic agents in rheumatoid arthritis in patients with an inadequate response to conventional disease-modifying antirheumatic drugs or to an anti-tumour necrosis factor agent: a meta-analysis. Ann Rheum Dis 2011 Feb;70(2):266-271.
Stettler C, Allemann S, Egger M, Windecker S, Meier B, Diem P. Efficacy of drug eluting stents in patients with and without diabetes mellitus: indirect comparison of controlled trials. Heart 2006 May;92(5):650-657.
Sultana A, Ghaneh P, Cunningham D, Starling N, Neoptolemos JP, Smith CT. Gemcitabine based combination chemotherapy in advanced pancreatic cancer-indirect comparison. BMC Cancer 2008;8:192.
Wilhelmus RK. Antiviral treatment and other therapeutic interventions for herpes simplex virus epithelial keratitis. Cochrane Database of Systematic Reviews 2011;7.
Wu P, Wilson K, Dimoulas P, Mills EJ. Effectiveness of smoking cessation therapies: a systematic review and meta-analysis. BMC Public Health 2006;6:300.
Zhou Z, Rahme E, Pilote L. Are statins created equal? Evidence from randomized trials of pravastatin, simvastatin, and atorvastatin for cardiovascular disease prevention. Am Heart J 2006 Feb;151(2):273-281.
Bayesian MTC but other than closed loop (n=13)
Bergman GJ, Hochberg MC, Boers M, Wintfeld N, Kielhorn A, Jansen JP. Indirect comparison of tocilizumab and other biologic agents in patients with rheumatoid arthritis and inadequate response to disease-modifying antirheumatic drugs. Semin Arthritis Rheum 2010;39(6):425-441
Edwards SJ, Clarke MJ, Wordsworth S, Welton NJ. Carbapenems versus other beta-lactams in the treatment of hospitalised patients with infection: a mixed treatment comparison. Curr Med Res Opin 2009;25(1):251-261
Freemantle N, Tharmanathan P, Herbrecht R. Systematic review and mixed treatment comparison of randomized evidence for empirical, pre-emptive and directed treatment strategies for invasive mould disease. J Antimicrob Chemother 2011 66(Suppl 1):25-35.
Jansen JP. Self-monitoring of glucose in type 2 diabetes mellitus: a Bayesian meta-analysis of direct and indirect comparisons. Curr Med Res Opin 2006;22(4):671-681.
Jansen JP, Bergman GJ, Huels J, Olson M. Prevention of vertebral fractures in osteoporosis: mixed treatment comparison of bisphosphonate therapies. Curr Med Res Opin 2009;25(8):1861-1868.
Jansen JP, Bergman GJ, Huels J, Olson M. The efficacy of bisphosphonates in the prevention of vertebral, hip, and nonvertebral-nonhip fractures in osteoporosis: a network meta-analysis. Semin Arthritis Rheum 2011;40(4):275-84.e1-2.
Mills EJ, Rachlis B, Wu P, Devereaux PJ, Arora P, Perri D. Primary prevention of cardiovascular mortality and events with statin treatments: a network meta-analysis involving more than 65,000 patients. J Am Coll Cardiol 2008;52(22):1769-1781.
Mills EJ, Perri D, Cooper C, Nachega JB, Wu P, Tleyjeh I, et al. Antifungal treatment for invasive Candida infections: a mixed treatment comparison meta-analysis. Ann Clin Microbiol Antimicrob 2009;8:23.
Mills EJ, Wu P, Chong G, et al. Efficacy and safety of statin treatment for cardiovascular disease: a network meta-analysis of 170,255 patients from 76 randomized trials. QJM 2011;104(2):109-124.
Quilici S, Abrams KR, Nicolas A, et al. Meta-analysis of the efficacy and tolerability of pramipexole versus ropinirole in the treatment of restless legs syndrome. Sleep Med 2008;9(7):715-726.
Quilici S, Chancellor J, Lothgren M, et al. Meta-analysis of duloxetine vs. pregabalin and gabapentin in the treatment of diabetic peripheral neuropathic pain. BMC Neurol 2009;9:6.
Stettler C, Allemann S, Wandel S, et al. Drug eluting and bare metal stents in people with and without diabetes: collaborative network meta-analysis. BMJ 2008;337:a1331.
Thompson Coon JS, Liu Z, Hoyle M, Rogers G, Green C, Moxham T, et al. Sunitinib and bevacizumab for first-line treatment of metastatic renal cell carcinoma: a systematic review and indirect comparison of clinical effectiveness. Br J Cancer 2009;101(2):238-243.
Protocol or abtract (n=3)
Le Cleach L, Trinquart L, LebrunVignes B, Giraudeau B, Chosidow O. Oral antiviral therapy for prevention of genital herpes outbreaks in immunocompetent and nonpregnant patients. Cochrane Database of Systematic Reviews 2009;1.
Filippini G, Vacchi L, D'Amico R, Di Pietrantonj C, Beecher D, Salanti G. Comparative efficacy and acceptability of immunomodulators and immunosuppressants for multiple sclerosis: overview of Cochrane systematic reviews and multiple-treatments meta-analysis. Cochrane Database of Systematic Reviews 2011;1.
Kyrgiou M, Salanti G, Pavlidis N, Paraskevaidis E, Ioannidis J. Multiple treatment meta-analysis: application in ovarian cancer chemotherapy [abstract]. XIV Cochrane Colloquium 2006 October 23-26, Dublin:163-Irean.