# Literature Search for Part Two

1. Randomized Controlled Trial/
2. Clinical Trial/
3. randomi$ control$ trial$.tw.
4. controlled clinical trial.sh.
5. clinical trial$.tw.
6. trial$.tw.
7. 1 or 2 or 3 or 4 or 5 or 6
8. review literature/
9. meta-analysis.sh.
10. meta-analy$.tw.
11. metaanaly$.tw.
12. (meta adj analy$).tw.
13. 8 or 9 or 10 or 11 or 12
14. (indirect adj2 comparison$).tw.
15. (indirect adj2 evaluat$).tw.
16. (indirectly adj2 compare$).tw.
17. bayesian.tw.
18. (mixed treatment adj compar$).tw.
19. MTC.tw.
20. 14 or 15 or 16 or 17 or 18 or 19
21. 7 and 13
22. 20 and 21
23. limit 22 to english language
24. limit 23 to yr=“2006 -Current”
25. remove duplicates from 24