# Abbreviations

AHRQ: Agency for Healthcare Research and Quality
BaSiS: Bayesian Standards in Science
CADTH: Canadian Agency for Drugs and Technologies in Health
CRD: Center for Reviews and Dissemination
DERP: Drug Effectiveness Review Program
DIC: deviance information criterion
DSU: Decision Support Unit
EHC: Effective Health Care
EPC: Evidence-based Practice Center
HIQA: Health Information and Quality Authority
ICWG: Indirect Comparisons Working Group
INAHTA: International Network of Agencies for Health Technology Assessment
ISPOR: International Society of Pharmacoeconomics and Health Outcomes Researchers
MTC: mixed treatment comparison
MTM: mixed treatment meta-analysis
NICE: National Institute for Health and Clinical Excellence
OHSU: Oregon Health & Science University
RCT: randomized-controlled trial
ROBUST: Reporting of Bayes Used in Clinical Studies
SD: standard deviation