# References

1 Federal Coordinating Council for Comparative Effectiveness Research, United States Department of Health and Human Services. Report to the President and the Congress. Available at: http://www.hhs.gov/recovery/programs/cer/cerannualrpt.pdf. May 29, 2011.
2 Agency for Healthcare Research and Quality. What is the effective health care program. Available at: http://www.effectivehealthcare.ahrq.gov/index.cfm/what-is-the-effective-health-care-program1/. November 24, 2010.
3 Lieberman JA, Stroup TS, McEvoy JP, et al. Effectiveness of antipsychotic drugs in patients with chronic schizophrenia. N Engl J Med. 2005;353(12):1209-23. [pmid: 16172203].
4 Perlis RH, Ostacher MJ, Patel JK, et al. Predictors of recurrence in bipolar disorder: primary outcomes from the Systematic Treatment Enhancement Program for Bipolar Disorder (STEP-BD). Am J Psychiatry. 2006;163(2):217-24. [pmid: 16449474].
5 Ziffra MS, Gilmer WS. STAR*D: Lessons learned for primary care. MBL Communications. 2007;14(1):8.
6 Rush AJ. Limitations in efficacy of antidepressant monotherapy. J Clin Psychiatry. 2007;68(Suppl):108-10.
7 Lehman AF, Steinwachs DM, The Survey Co-Investigators of the PORT Project. Patterns of usual care for schizophrenia: initial results from the schizophrenia Patient Outcomes Research Team (PORT) Client Survey. Schizophr Bull. 1998;24(1):11-20. [pmid: 9502543].
8 National Comorbidity Survey. 12-month prevalence of DSM-IV/WMH-CIDI disorders by sex and cohort. 2007.
9 Kessler RC, Wang PS. The descriptive epidemiology of commonly occurring mental disorders in the United States. Annu Rev Public Health. 2008:29115-29.
10 Kessler RC, Chiu WT, Colpe L, et al. The prevalence and correlates of serious mental illness (SMI) in the National Comorbidity Survey Replication (NCS-R) Website. n.d. Available at: http://mentalhealth.samhsa.gov/publications/allpubs/SMA06-4195/Chapter15.asp. April 29, 2010.
11 Ruggeri M, Leese M, Thornicroft G, et al. Definition and prevalence of severe and persistent mental illness. Br J Psychiatry. 2000:177149-55.
12 Peck MC, Scheffler RM. An analysis of the definitions of mental illness used in state parity laws. Psychiatr Serv. 2002;53(9):1089-95. [pmid: 12221306].
13 Kessler RC, Galea S, Jones RT, et al. Mental illness and suicidality after Hurricane Katrina. Bull World Health Org. 2006.
14 David A, Adams CE, Eisenbruch M, et al. Depot fluphenazine decanoate and enanthate for schizophrenia. Cochrane Database Syst Rev. 2004;(2).
15 National Advisory Mental Health Council. Health care reform for Americans with severe mental illnesses: report of the National Advisory Mental Health Council. Am J Psychiatry. 1993;150(10):1447-65. [pmid: 8379547].
16 Bartels SJ, Levine KJ, Shea D. Community-based long-term care for older persons with severe and persistent mental illness in an era of managed care. Psychiatr Serv. 1999;50(9):1189-97. [pmid: 10478906].
17 Schinnar AP, Rothbard AB, Kanter R, et al. An empirical literature review of definitions of severe and persistent mental illness. Am J Psychiatry. 1990;147(12):1602-8. [pmid: 2244636].
18 Substance Abuse and Mental Health Services Administration. Mental health dictionary National Mental Health Information Center Webpage. Available at: http://www.samhsa.gov/healthreform/healthhomes/Definitions_SIM_SUD_508.pdf. June 4, 2010.
19 Center for Substance Abuse Treatment. Definitions and Terms Relating to Co-Occurring Disorders. DHHS Publication No. (SMA) 06-4163, COCE Overview Paper 1. Rockville, MD. Substance Abuse and Mental Health Services Administration, Department of Health and Human Services. 2006.
20 Manderscheid RW, Druss B, Freeman E. Data to manage the mortality crisis: Recommendations to the Substance Abuse and Mental Health Services Administration. Washington, D.C. Substance Abuse and Mental Health Services Administration. 2007.
21 Wang PS, Lane M, Olfson M, et al. Twelve-month use of mental health services in the United States: results from the national comorbidity survey replication. Arch Gen Psychiatry. 2005;62(6):629-40. [pmid: 15939840].
22 National Institute of Mental Health. The numbers count: mental disorders in America. Available at: http://www.nimh.nih.gov/health/publications/the-numbers-count-mental-disorders-in-america/index.shtml. April 29, 2010.
23 Insel TR. Assessing the economic costs of serious mental illness. Am J Psychiatry. 2008;165(6):663-5. [pmid: 18519528].
24 World Health Organization. Disease control priorities related to mental, neurological, developmental and substance abuse disorders. Geneva, Switzerland. World Health Organization. 2006.
25 Greenberg PE, Kessler RC, Birnbaum HG, et al. The economic burden of depression in the United States: how did it change between 1990 and 2000?. J Clin Psychiatry. 2003;64(12):1465-75. [pmid: 14728109].
26 National Alliance on Mental Illness. The impact and cost of mental illness: the case of bipolar disorder Website. Available at: http://www.nami.org/Content/NavigationMenu/Inform_Yourself/About_Public_Policy/Policy_Research_Institute/Policymakers_Toolkit/Impact_and_Cost_of_Mental_Illness_Bipolar.htm. April 28, 2010.
27 Merikangas KR, Akiskal HS, Angst J, et al. Lifetime and 12-month prevalence of bipolar spectrum disorder in the National Comorbidity Survey replication. Arch Gen Psychiatry. 2007;64(5):543-52. [pmid: 17485606].
28 Kessler RC, Birnbaum H, Demler O, et al. The prevalence and correlates of nonaffective psychosis in the National Comorbidity Survey Replication (NCS-R). Biol Psychiatry. 2005;58(8):668-76. [pmid: 16023620].
29 Regier DA, Narrow WE, Rae DS, et al. The de facto US mental and addictive disorders service system. Epidemiologic catchment area prospective 1-year prevalence rates of disorders and services. Arch Gen Psychiatry. 1993;50(2):85-94. [pmid: 8427558].
30 Wu EQ, Birnbaum HG, Shi L, et al. The economic burden of schizophrenia in the United States in 2002. J Clin Psychiatry. 2005;66(9):1122-9. [pmid: 16187769].
31 Kessler RC, Chiu WT, Demler O, et al. Prevalence, severity, and comorbidity of 12-month DSM-IV disorders in the National Comorbidity Survey Replication. Arch Gen Psychiatry. 2005;62(6):617-27. [pmid: 15939839].
32 Epstein J, Barker P, Vorburger M, et al. Serious mental illness and its co-occurrence with substance use disorders, 2002. DHHS Publication No. SMA 04-3905, Analytic Series A-24. Rockville, MD. Sustance Abuse and Mental Health Services Administration, Office of Applied Studies. 2004.
33 Stroup TS, McEvoy JP, Swartz MS, et al. The National Institute of Mental Health Clinical Antipsychotic Trials of Intervention Effectiveness (CATIE) project: schizophrenia trial design and protocol development. Schizophr Bull. 2003;29(1):15-31. [pmid: 12908658].
34 Sachs GS, Thase ME, Otto MW, et al. Rationale, design, and methods of the systematic treatment enhancement program for bipolar disorder (STEP-BD). Biol Psychiatry. 2003;53(11):1028-42. [pmid: 12788248].
35 Rush AJ, Fava M, Wisniewski SR, et al. Sequenced treatment alternatives to relieve depression (STAR*D): rationale and design. Control Clin Trials. 2004;25(1):119-42. [pmid: 15061154].
36 Wagner EH, Austin BT, Davis C, et al. Improving chronic illness care: translating evidence into action. Health Aff (Millwood). 2001;20(6):64-78. [pmid: 11816692].
37 Bellack AS. Scientific and consumer models of recovery in schizophrenia: concordance, contrasts, and implications. Schizophr Bull. 2006;32(3):432-42. [pmid: 16461575].
38 Insel TR. Rethinking schizophrenia. Nature. 2010;468(7321):187-93. [pmid: 21068826].
39 Institute of Medicine. Initial national priorities for comparative effectiveness research. Washington, DC. National Academy of Sciences. 2009.