# Methods

## Stakeholder Engagement

We sought a broad array of stakeholder opinions to balance perspective, minimize bias, and ensure that diverse perspectives were reflected. We made sure to include stakeholders who represented important subpopulations, such as those with ethnic, cultural, socioeconomic, or racial disparities associated with SMI.

Stakeholders were identified by input from the RTI-UNC EPC, AHRQ, and the Scientific Resource Center, and they represented a cross-section of patients, family members, consumers, advocates, practicing clinicians, professional societies, policymakers, public and private payers, Federal agencies, researchers, and methodologists. We used standard recruitment practices to secure participation. Stakeholders were contacted via telephone followed by a written e-mail invitation that included a brief overview of the IEF. Those stakeholders who declined to participate were asked to provide a substitute from their organization or who represented their perspective if there was no organizational affiliation, to ensure a broad and balanced representation. If a substitute was unavailable, we used a substitution list to find a comparable replacement.

Preparation. Confirmed participants were offered an orientation on AHRQ and the EHC Program. Orientation sessions reviewed the history, goals, and objectives of the EHC Program, discussed AHRQ research processes most relevant to the forum (topic generation, nomination, and selection), discussed the goals and objectives of the forum, and reviewed expected roles of participants in the forum. A brief outline of all EHC Program public involvement opportunities was also included. Several dates and times were offered over the course of 3 weeks before the forum began. The sessions were conducted using a Web-hosted PowerPoint presentation. Participants received a PDF version of the presentation, the Federal Coordinating Council's definition of CER, a brief definition of a PICOTS (Patients, Interventions, Comparators, Outcomes, Treatments, Settings) framework for research synthesis questions, and a draft version of the EHC Program selection criteria for new research.

Prior to the IEF phone and in-person meetings, participants received materials by e-mail. Materials included documents describing the background and objectives of the forum, the definition of CER and related terminology, the definition of SMI and the scope of the forum, the organizing framework, a process summary for determining the focus area of the forum, draft selection criteria for new research, examples of mental health CER/PCOR topics, a summary of the burden of SMI, past CER tables, a summary of the populated organizing framework, a populated framework, and an environmental scan bibliography.

Topic generation. To generate topics, three meetings were held; the first and third meetings were held via conference call, using Web-hosted presentations, whereas the second was an all-day, in-person meeting at the AHRQ offices in Rockville, Maryland. A professional facilitator was used to aid the discussion during all meetings.

The objectives of the first meeting were to introduce the goals and format, and to gather initial feedback related to stakeholder areas of interest. At the meeting, participants received a brief summary of the meeting materials described above, and then discussed them by providing feedback in the areas of greatest interest related to research on SMI.

We invited participants to continue the discussion and submit research ideas and broader ideas using an online forum hosted by AHRQ. They received login information and instructions for posting to the online forum. Potential research topics were accepted for 5 days following the meeting. We also accepted topics by e-mail and phone and posted them on behalf of participants to the online forum. The suggestions made by participants readily grouped into three main themes: (1) patient-centered care—improving outcomes that matter to patients, (2) conceptual frameworks for research, and (3) reduction of disparities for subpopulations.

The objectives of the in-person meeting (second meeting) were to discuss broad issues in the area, identify gaps, and generate and prioritize research topics that can address these issues and gaps. Participants received meeting materials via e-mail in advance and binders with hard copies of related materials at the meeting.

Participants were pre-assigned to one of three workgroups corresponding to the themes emerging from the potential research topics that participants suggested during and following the first meeting. Group assignments were made to balance perspectives in each of the workgroups. Each workgroup reviewed the list of previously submitted topics in its theme and generated additional topic ideas through facilitated group discussion. The workgroups presented brief overviews of their discussions and reviewed the additional topic ideas generated. All topic ideas were recorded and displayed in the meeting room. Following a facilitated discussion of the full group, participants offered amendments using a rolling feedback process. Suggested changes were written on self-adhesive notes and placed next to the appropriate topic idea.

Topic prioritization. After final review and discussion, a nominal group process was used to identify initial priorities. Stakeholders used stickers to indicate which topics should be given highest priority for research. Participants were allotted 20 stickers, and allowed to place between 1 and 5 stickers on any one topic idea. We tallied the stickers and reported the results of the initial prioritization to the group. All topic ideas were captured in meeting notes for further analysis.

Organization of prioritized topics into common themes. Following the in-person meeting, we sorted and organized the topics by theme across the meeting workgroups. Topics were qualitatively assessed by teams of investigators and compared both within and across initial groupings. Special attention was given to topics that were closely related. Topics were then exchanged with other teams and reanalyzed. We organized the topics from the second meeting into 21 common topic themes. Two documents were created to organize results and display the topics according to priority, based on the number of stickers received at the in-person meeting.

The objectives of the final meeting were to review the prioritized topic themes, gather feedback on the process used to organize the prioritized topics, and get a preliminary sense of which topics are appropriate for evidence synthesis, evidence generation, and other research activities and products. Before the meeting, participants received the list of prioritized topics and were given a chance to give feedback and to comment on the list.