# Introduction

Comparative effectiveness or patient-centered outcomes research (CER/PCOR) has been defined by the Federal Coordinating Council for CER as “the conduct and synthesis of research comparing the benefits and harms of different interventions and strategies to prevent, diagnose, treat and monitor health conditions in ‘real world’ settings.”1 The purpose of CER/PCOR is “to improve health outcomes by developing and disseminating evidence-based information to patients, clinicians, and other decisionmakers, responding to their expressed needs, about which interventions are most effective for which patients under specific circumstances.”1 The interventions compared may include medications, procedures, medical and assistive devices and technologies, diagnostic tests, behavioral changes, and delivery system strategies.1 CER/PCOR designs may include clinical trials, observational studies, secondary analyses of databases, systematic reviews with or without meta-analyses, and cost-effectiveness analyses. CER/PCOR is conducted within a framework that encompasses a variety of activities as illustrated in Figure 1. All of these activities are ultimately aimed at improving health care.

Figure 1 Framework for comparative effectiveness research

Figure 1: Flowchart illustrating the framework for comparative effectiveness research model.

The Agency for Healthcare Research and Quality (AHRQ) is the lead Federal agency charged with improving the quality, safety, efficiency, and effectiveness of health care for all Americans. As 1 of 12 agencies within the Department of Health and Human Services, AHRQ supports health services research to improve the quality of health care and promote evidence-based decisionmaking; AHRQ supports a variety of CER/PCOR activities through its Effective Health Care (EHC) Program.2 The EHC Program funds individual researchers, research centers, and academic organizations that work with AHRQ to produce effectiveness and comparative effectiveness research for clinicians, consumers, and policymakers. To contribute to its agenda for CER/PCOR activities related to mental health, AHRQ contracted the RTI International-University of North Carolina (RTI-UNC) Evidence-based Practice Center (EPC) and the Scientific Resource Center Stakeholder Engagement Team to engage a broad and representative group of stakeholders to discuss issues related to serious mental illness (SMI) in a series of three meetings (Issues Exploration Forum [IEF]), as detailed in the methods section.

The results of three large comparative effectiveness trials have been sobering, and arguably have highlighted the limitations of our current ability to help many patients afflicted with schizophrenia, bipolar disorder, and depression. The Clinical Antipsychotic Trials of Intervention Effectiveness (CATIE) study reported that an older typical antipsychotic medication was as effective as the newer, more publicized atypical antipsychotics when used as a first-line treatment. In addition, nonadherence to medication was the norm, not the exception, with almost 75 percent of patients not using their medication after 18 months of treatment.3 The Systematic Treatment Enhancement Program for Bipolar Disorder (STEP-BD) trial reported that about 40 percent of bipolar patients do not recover from a manic episode.4 In addition, for those who do recover, the relapse rates for either a subsequent depressive or manic episode were about 50 percent over the following 2 years. In the Sequenced Treatment Alternatives to Relieve Depression (STAR*D) trial, after 13 weeks of treatment with a selective serotonin reuptake inhibitor only a third of patients met remission criteria.5 Furthermore, after another 39 weeks of treatment only another third of the initial cohort remitted, leaving a full third of patients symptomatic.6 Reports from the Schizophrenia Patient Outcomes Research Team (PORT) underscore the point that effective treatments are available, but implementation and uptake are suboptimal.7

More than 30 percent of the U.S. population suffers from a mental illness each year.8 Of this group, 22 percent are classified as serious, 37 percent as moderate, and 40 percent as mild.9 In sum, about 17.8 million people (5.8 percent of the U.S. population) live with SMI in any given year, resulting in significant economic and societal consequences. Several working definitions of SMI, severe mental illness, or severe and persistent mental illness have been used.10-18 For this IEF's purposes, we used the following criteria to define adults with SMI:18 people who (1) are ages 18 or older; (2) currently have, or at any time during the past year had, a diagnosable mental, behavioral, or emotional disorder of sufficient duration to meet diagnostic criteria specified within the Diagnostic and Statistical Manual of Mental Disorders, 4th Edition (DSM-IV) or the International Classification of Diseases, 9th Revision, Clinical Modification (ICD-9-CM) equivalent (and subsequent revisions); and (3) have functional impairment that substantially interferes with or limits one or more major life activities. Major life activities (in part 3 of the definition) include basic daily living skills (e.g., eating, maintaining personal hygiene); instrumental living skills (e.g., managing money, negotiating transportation, taking medication as prescribed); and functioning in social, family, and vocational or educational contexts.19

American adults living with SMI die about 25 years earlier than other Americans, largely owing to treatable medical conditions.20 In fact, many people with SMI do not seek any health care.21 On average, those with SMI report being totally unable to carry out their normal daily activities for 88 days per year compared with 4.7 and 1.9 days, respectively, for those classified as having a moderate or mild mental illness.9 SMI is the second-leading cause of disability in the United States for ages 15 to 44^22^ and accounts for between 5,000 and 10,000 disability-adjusted life years lost worldwide per year per 1 million population.

In 2002, SMI was estimated to cost more than $100 billion in health care expenditures alone.23 Loss of earnings as a result of SMI was estimated to be about $193 billion, and disability benefits cost an additional $24.3 billion, resulting in a total of more than $317 billion spent on SMI in 2002.^23^ SMI represents the largest diagnostic category for people receiving Supplemental Security Income (SSI) and Social Security Disability Insurance (SSDI) payments from the Federal Government. Table 1 provides data on the burden of disease associated with SMI and mood and psychotic disorders.

Table 1 The burden of serious mental illness: Mood and psychotic disorders^**^

Mental Health Disorder | Prevalence^*^ (12-month) % | Mental Health Services Utilization (12-month)^†^ % | % of Total DALYs in High-Income Countries % | Cost (direct and indirect; adjusted to 2010 dollars) $ (Billions)
Any mental health disorder | 32.4^8^ | 41.1^21^ | 20.9^24^ | —
Serious mental illness | 5.8^21^ | — | — | $383.5^23^
Mood Disorders
Any mood disorder | 9.7^8^ | 56.4^21^ | — | —
Major depressive disorder | 6.8^8^ | 56.8^21^ | 5.6^24^ | $105^25^
Dysthymia | 1.5^8^ | 67.5^21^ | — | —
Any bipolar disorder | 2.8^8^ | 55.5^21^ | 0.71^24^ | $72.2^26^
Bipolar I | 0.6^27^ | — | — | —
Bipolar II | 0.8^27^ | — | — | —
Subthreshold bipolar disorder | 1.4^27^ | — | — | —
Psychotic Disorders
Any nonaffective^**^ psychosis | 1.5^28^ | — | — | —
Schizophrenia | 1.1^29^ | — | 0.75^24^ | $76^30^

DALY= disability-adjusted life year.

* “12-month prevalence” refers to the proportion of study participants who identified symptoms occurring in the 12 months preceding the study interview that could be categorized as a mental health disorder.

** “Lifetime prevalence” was estimated based on the proportion of respondents who had ever had the mental health disorder at the time of the interview. Mood disorders are broadly recognized as either depressive disorders, including major depressive disorder (MDD) or bipolar disorder (BD). MDD affects approximately 14.8 million American adults, or 6.8% of the U.S. population ages 18 and older in a given year.31 Of the 9.7% of the population diagnosed with mood disorders in a 12-month period, 45% are classified as serious.9 About 30% of MDDs, 50% of dysthymias, and 83% of BDs are serious.9

† Receiving any treatment in the 12 months before interview, by a psychiatrist, general practitioner, family physician, any other physician, social worker, counselor, any other mental health professional, religious or spiritual advisor, or any other healer.

We limited the scope of the IEF to adults with SMI who have psychotic or mood disorders because these disorders account for the majority of SMI and because our time and resources were limited. We did not include alcohol- and substance-related disorders, developmental disorders, anxiety disorders, or personality disorders, unless they co-occurred with a psychotic or mood disorder. Figure 2 illustrates the focus of the IEF and the relationship among SMI, mood disorders, and psychotic disorders.

Figure 2 The relationship between SMI, mood disorders, and psychotic disorders (this IEF focused on adults with SMI who have psychotic or mood disorders)

Sources: National Comorbidity Survey.8 Epstein J, et al.32

Figure 2: Venn diagram illustrating the relationship between SMI, mood disorders, and psychotic disorders (this IEF focused on adults with SMI who have psychotic or mood disorders)

The overarching purpose of this Issues Exploration Forum was to contribute to the establishment of priorities to guide CER/PCOR activities in mental health by engaging a diverse group of stakeholders. We aimed to focus on an area of mental health with significant unmet need despite available interventions and an area in which conducting CER/PCOR is likely to have an impact on reducing variation and uncertainty in clinical practice and outcomes, reducing methodological and conceptual uncertainty, and reducing disease burden. Additional objectives were to identify knowledge gaps in the area of SMI and to generate and prioritize topics for future CER/PCOR, including topics for evidence synthesis (i.e., systematic reviews, comparative effectiveness reviews).