# Acknowledgments

The investigators deeply appreciate the considerable support, commitment, and contributions of the Scientific Resource Center and Evidence-based Practice Center (EPC) staff at RTI International and the University of North Carolina. We extend our appreciation to the RTI International EPC project manager, Carol Woodell. We express our gratitude to Scientific Resource Center staff Lynn Rosenberg, as well as RTI staff Loraine Monroe, our EPC publications specialist, and Laura Small, senior editor. Finally, we greatly appreciate the commitment and contribution of Sonia Tyutyulkova, MD, PhD, the AHRQ Task Order Officer for this project, for providing the conceptual framework and guidance throughout the project.