# Discussion

## Need To Fundamentally Change Our Approach to Clinical Research for Serious Mental Illness

The topics prioritized by stakeholders deviated somewhat from our expectations. We had anticipated that stakeholders would focus mostly on head-to-head comparisons of evidence-based treatments or interventions, or on studies to fill gaps in the literature. Instead, three of the top four priorities focused on how research was conducted, namely (1) developing consensus measurement and outcomes definitions; (2) improving infrastructure for research, longitudinal studies, new data sets, and new investigators; and (3) developing CER/PCOR methodology. These findings highlight a feeling expressed by many stakeholders: failure to fundamentally change the way research on SMI is conducted will significantly prevent the field from moving forward.

Briefly examining landmark studies conducted over the last decade may explain how and why this occurred. First, the CATIE, STEP-BD, and STAR*D trials reported very sobering results, clearly demonstrating that our treatments are not as effective as we might have hoped.33-35 Most patients with a psychotic disorder and many patients with a mood disorder suffer significant morbidity. Although those studies were originally designed in the late 1990s, arguably no new pharmacological or psychosocial treatments have become available since then that could be considered “game changers.” Despite the pessimism, PORT7 reports highlight a number of both types of treatments that are clearly superior to placebo, though almost all available treatment algorithms typically characterize these independently (i.e., separate algorithms for each). Further, the rates at which patients' treatment conformed to PORT recommendations were modest at best (generally below 50 percent), and rates were higher for pharmacological than for psychosocial treatments, and in rural areas than in urban areas.7

As the results of large comparative effectiveness trials like CATIE, STEP-BD, and STAR*D have become available, there is a growing recognition that although most SMI is a chronic lifetime disorder, most current research evaluates outcomes after an intervention over a much shorter time frame.33-35 Long-term studies reporting the most important outcomes (e.g., disability, functional ability, and quality of life) are lacking for people with SMI despite the chronic and disabling nature of these conditions. How does one rationally place treatments with 6-week to, at most, 1- to 2-year outcomes, typical in previous pharmacologic and psychosocial intervention trials, in the framework of an illness that will last 30, 40, or 50 years? How would one actually assess outcomes in a lifelong illness? Many individuals with SMI are initially diagnosed in their 20s. Thus, they live the majority of their lives with considerable disabilities in comparison with people who do not have the illness. Given this, our current model for treatment may need to shift to one that is more consistent with a chronic illness model of care. This shift has occurred with certain medical illnesses with some benefits reported.36 Interestingly, stakeholders emphasized the value of the therapeutic relationship in the treatment of chronic mental illness and the need for further CER/PCOR to clearly consider or further evaluate the role of the therapeutic relationship. A good therapeutic relationship is critical for many aspects of successful treatment, including engagement in treatment, and is very consistent with a chronic illness model of care.

Perhaps the most significant change in the conceptualization of severe mental illness over the past 20 years has been the emergence of the Recovery Model.37 The main impetus for this change came from consumers themselves, who felt that the classic medical model of disease led to unnecessary stigmatization and the perception of hopelessness. Although there is strong evidence of continuing morbidity for most patients with SMI, there is also strong evidence that the vast majority of patients do not progressively deteriorate over time, and that as many as 50 percent to 70 percent of people with schizophrenia can go on to work and have “productive” lives. There are 10 core components of the Recovery Model with an emphasis on choice, empowerment, and hope. The model focuses on people's strengths, not their symptoms. Recovery from a major mental illness is seen similarly to recovery from a severe myocardial infarction. Individuals may have a damaged myocardium, but they are people with other aspects to their lives and are not wholly characterized with labels as cardiac patients. Currently, there is very limited research on this model.

On the surface there seems to be a possible disconnect between talking about “recovery” on one hand and suggesting on the other hand that this is a chronic lifetime illness that needs to be studied long term. However, it may well be that the stakeholders (who included two consumers) were also getting at the different phases of chronic mental illness. Although most of the research has been on the more acute phase of the illness, most individuals spend the vast majority of their illness in the nonacute phase. A recent published report suggested that schizophrenia could be conceptualized as a neurodevelopmental disorder with a later onset psychotic portion.38 More research on what factors promote recovery over the long term would seem to be consistent with both models.

## Comparisons of Evidence-Based Interventions and Addressing Knowledge Gaps

Although the top priorities centered on the need to revamp the research framework, stakeholders also identified a number of priority interventions for comparative effectiveness research. Service delivery, treatment settings, and structuring the delivery of care were identified as priority interventions for CER/PCOR (priority 3), which is not surprising and seems to follow a trend. Close to half of all mental health topics in the Institute of Medicine report Initial National Priorities for Comparative Effectiveness Research are related to systems and delivery of care.39 The Federal Coordinating Council for CER also noted that CER to date “has been disproportionately focused on pharmacologic treatments rather than the full spectrum of intervention types” and further concluded that “the emphasis on pharmacologic treatments has meant fewer resources for other interventions, including behavioral, procedures, prevention, and delivery system interventions that can have major impacts on health outcomes.”1 Comparisons of treatment approaches to avoid early morbidity and mortality were highlighted as a priority (priority 8). A point of emphasis at the in-person meeting was that people with SMI die 25 years earlier20 on average and that something must be done to improve this early mortality. Comparisons of strategies to personalize and individualize treatment and to increase adherence to evidence-based guidelines and treatment regimens, including the role of EMRs and decision support, were identified as other priority interventions for CER/PCOR.

## Priority Populations

Stakeholders identified two priority populations as targets for CER/PCOR: people with SMI and comorbid medical illness or substance abuse and people with SMI involved in the criminal justice system (priorities 8, 12, and 13). A need for research focused on specific ethnic and racial communities and a need to identify disparities and the reasons for disparities related to access, systems issues, institutional racism, and lack of services to people with limited English-language skills (priority 5) highlight additional possible targets for CER/PCOR.

## Using Stakeholder Engagement to Identify Priorities for Research

The process used to establish research priorities during the IEF was considered successful. Engagement of a broad and representative group of stakeholders in a transparent process driven by the participants and aided by a neutral facilitator resulted in the identification of knowledge gaps, broad conceptual and methodological issues related to research, and priority areas for CER/PCOR. Stakeholders with a variety of decisional needs identified their priorities and preferences, clearly indicating a need to change the way research on SMI is conducted, including a need for improved methodologies to result in better evidence, practice, and patient outcomes. Using a process similar to this IEF can provide a novel way to generate state-of-the-field thinking, allowing the overarching issues in a field to emerge. Even more robust results could likely be obtained by addressing identified process limitations. Resource constraints limited the number and scope of participants. Similarly, although the most productive part of the process was the in-person meeting (meeting 2), resources limited face-to-face interaction to a single meeting. We experienced attrition in participation at meeting 3 following the in-person meeting and a request for more face-to-face interaction from some stakeholders.

Many of the organizations that participated in the IEF were not initially familiar with the EHC Program and CER. To participate fully, they required the context provided at the optional orientation sessions and a basic understanding of how CER/PCOR might be beneficial to them. This was a critical step, especially for nonclinician/researcher participants. At the end of the process, the majority of participants indicated a basic understanding of CER/PCOR and the EHC Program as well as a willingness to continue to participate in similar processes. To that end, investigators and individual stakeholders are currently working together to advance priority topics for consideration in the EHC Program.

It was necessary to identify, define, and communicate to the stakeholders the variables that might have affected the outcome of the process and the stakeholder experience. These variables included the goal of the IEF, expected outputs, how stakeholders were involved and represented, how the process was facilitated, and what was driving the process.

Having a dedicated and neutral focus enhanced the likelihood of a successful process and outcome. It was important to have a topic-neutral “bridge” between stakeholders with different perspectives in the research process and to facilitate communication between stakeholders and researchers or program staff. Having a facilitator to act in a neutral capacity focused on process allowed us to establish common ground among myriad perspectives, communicate stakeholder interests in ways understandable by a research-savvy audience, and translate basic evidence-synthesis needs so that stakeholders could communicate their ideas in ways that could be acted upon by the EHC Program.

As stakeholder and public involvement in the research enterprise becomes increasingly expected, it will be important to invest in the processes and tools that enable successful engagement.