# Detailed Prioritized List of Topics

## Individual Topics Listed Under Corresponding Thread

(Number in bold in parentheses after each item indicates the number of times a stakeholder expressed a preference for that topic)

1. Measurement and outcomes need consensus definitions. (49) *
  * This topic was determined by the stakeholders to be appropriate for evidence synthesis.
  R NT = Conceptual framework for Research Workgroup–New Topic
  R T = Conceptual framework for Research Workgroup –Topic
  R I = = Conceptual framework for Research Workgroup–Idea
  PC = Patient-centered Workgroup
  D = Disparities Workgroup
  SH Note = Stakeholder Note
  - R NT2. Develop appropriate measurements for mental health research that are based in a chronic care model and are appropriate metrics for mental health, rather than the inadequate metrics that exist today that are based on an acute-care model. Must include defining more appropriate outcomes criteria, larger sample sizes, and longer-term studies that include followup over time. (22)
  - PC 31. Measurement and outcomes need consensus definitions. (14)
  - PC 39. Identify priority outcomes for consumers—facilitate consensus to develop. (8)
  - R NT10. Explore shared decisionmaking with patients in order to capture more information and to lead to more valid measures of coded medical data. (3)
  - PC 2. Compare the effectiveness of common treatments for people with SMI with regard to patient-centered and patient-relevant outcomes (e.g., disability, functional capacity, quality of life, employment, and housing). (2)
  - R NT19. Develop standardized assessments/tools for mental health, as they are currently lacking. (0)
  - R NT21. Identify standard, accepted mental health outcomes, like blood pressure is accepted (e.g., Patient Health Questionnaire [PHQ9] as part of records). (0)
  - R NT6. Need to encourage more standard and consistent documentation (in patient records) vs. reality vs. consumer/provider perspective. (0)
    i. SH Note: The way that documentation requirements (which are driven by a multiplicity of payers and regulatory agents) drive assessment, treatment, and the nature of the relationship between the clinician and the individual receiving care has not been well studied, either in terms of benefits in influencing quality or in terms of the “unintended consequences” of specific requirements that decreased quality. Attention to documentation and specific research to develop effective and efficient approaches is particularly important to enhancing interoperability to developing electronic health records that adequately meet the needs of professionals and patients.
2. Development of infrastructure for research: longitudinal studies, new investigators, and datasets. (47) *
  - R NT1. Infrastructure is needed that supports longitudinal studies including developing new investigators/investigator teams and providing additional training. (31)
  - PC 43. Facilitate infrastructure for comparable datasets (detailed registries)—consumers, care providers, interventions. (16)
3. Service delivery, treatment settings, and structuring the delivery of care. (44)
  - R NT8. Make treatment settings into experiments for studies. Explore which factors built into the structure of current health care contribute (or not) to patient adherence, especially for SMI—also consider differences in sectors (public or private), and develop needed criteria of evaluation success. (25)
    i. SH Note: Building an infrastructure for long-term research is critical, but it is expensive. Consider partnering with other agencies (e.g., National Institutes of Health, Department of Housing and Urban Development, Department of Justice, Department of Defense, and Department of Energy) to, for example, create a “superfund” to support long-term outcomes research.
  - D 33. Small area variations in overall well-being. (4)
    i. Gallup research.
    ii. Pharma only—no psychosocial support.
    iii. Scalability of small area intervention.
  - R NT11. Majority of people with SMI not getting care at all (never even touching the mental health care system), or not over time. This is not trivial. Must detect and care for mental health patients in general medical settings. (4)
    i. SH Note: Education/Medicaid database—but what if those functions/treatments/episodes of care are not applicable to the majority of people with mental illness who are not treated.
  - PC 33. Psychiatric medical home vs. usual care—impact on general health outcomes. (3)
  - PC 18. Compare the effectiveness of interventions for various SMI disorders across settings (community or real-world settings vs. academic settings). (3)
    i. SH Note: Compare and research the impact of trauma both in the community and the mental health system.
  - PC 12. Compare the effectiveness of different systems for structuring the delivery of care on outcomes including quality of life, functioning, individuals lost to followup, time spent in case management activities, and duration of untreated psychosis. For example: (a) state-to-state comparisons of systems with a pure catchment area approach with a single responsible entity vs. systems with a patchwork of hospitals and state, county, and voluntary outpatient programs; (b) public systems vs. various models of private insurance; (c) systems that deliver care in teams vs. those settings that deliver care in solo-health-practitioner or split-care arrangements (one prescriber and one distinct therapist). (2)
  - PC 7. For people with SMI, compare the effectiveness of medication treatment provided in the context of various health care delivery models or management strategies. (2)
    i. SH Note: Also include health care delivery tools (e.g., prior authorization) and their effect on medical treatment (e.g., does medical treatment happen? How does it change? Other classes of medications used instead?)
  - R I-6. There is a need to provide legal assistance to communities trying to bring about parity. States vary in the availability of treatments and services. (1)
  - R NT20. Treat service delivery systems as experiments. (0)
    i. Availability and linkability of data.
    ii. Consider application of practice-based evidence, rather than evidence-based practice as applied to mental health.
  - R NT25. Consider the sectors (public vs. private). (0)
  - R NT14. Current research models are driving treatment outcomes. (0)
    i. SH Note: In thinking about research methods and approaches, strong consideration should be give to the potential of qualitative research methods and formal medical decisionmaking analysis. The latter requires that data from existing trials be reported in terms of proportions rather than change in symptoms scores (e.g., x percent of those given treatment y have at least a 50 percent response in symptoms, a percentage of those treated with y develop side effect z). This information would be more clinically useful than knowing that the treatment leads to a statistically significant (but not clinically significant) effect.
  - R NT15. “Organizations of system” mirrors organization of research. (0)
    i. SH Note: The infrastructure daily registry development should involve the National Institute of Mental Health to have standardization and linkage to emerging research around enhancing the registry elements and for generalizability of research findings to natural solutions.
    ii. SH Note: Framework—amend the measure development—we desperately need this for behavioral health.
    iii. R NT16. Careful measurements over time. (0)
    iv. R NT17. Observational research to art. (0)
    v. R NT18. Center Stone of American framework. (0)
    vi. TN—Partnered with Vanderbilt.
    vii. Knowledge network.
    viii. Large infrastructure.
  - D 41. After “first break” compare outcomes between private vs. public insurance. (0)
  - D 58. Ethnic-specific provider supports. (0)
  - D 26. How does variation across systems and states affect subpopulations? (0)
  - D 45. Compare the effectiveness of various methods to improve provider communication between primary care providers and mental health providers. (0)
4. Development of CER/PCOR methodology. (40)
  - R NT7. Need to develop methodology for CER/PCOR for mental health. Need methods to adjust for confounding post-baseline (i.e., during followup)—using global measures of functioning (e.g., more work is needed to use performance-based measures in mental health research for increased validity and reliability for mental health). (20)
  - R NT3. Develop a mental health study design that includes how to control for nonspecific affects, outcomes relevant for real-life settings, as current a particular limitation for mental health is that short-term clinical trials do not translate well into long-term trials. (7)
    i. SH Note: Research on psychosocial and psychotherapeutic interventions requires a guiding taxonomy/framework to define and describe approaches. For instance, labeling/grouping of treatments varies considerably (depending on investigators and available data) across systematic reviews and randomized controlled trials. For instance, mindfulness-based cognitive therapy, cognitive behavioral therapy (CBT) vs. cognitive vs. problem-solving therapy, etc., for major depressive disorder. Should these be evaluated as distinct treatments or are they better viewed as minor variations (or replications) within a broader CBT model? The importance of such a taxonomy for grouping analysis and comparison of treatments cannot be emphasized enough! What are “common”/“necessary” components to distinguish CBT, NS interpersonal psychotherapy vs. psychodynamic psychotherapy?
  - D 36. Research/reevaluation of priorities in biological vs. psychosocial research. There needs to be better integration of these—need to consider the whole person. (7)
  - PC 3. Compare the long-term effectiveness of psychotropic medications or other interventions for people with SMI. (3)
    i. SH Note: Pharmaceutical track record regarding not raising and/or suppressing negative data; their particular medications makes the involvement of Big Pharma highly suspect.
  - R T3. Compare the effectiveness of different levels of consumer and patient involvement in topic generation, topic development and refinement, and input related to research design. (2)
  - R I-10. The use of qualitative approaches has not been adequately exploited. Some interventions could be subjected to qualitative research methods. (1)
  - R NT23. Explore and expand the use of new and different analyses (e.g., propensity scores, time series, IVs in CER/PCOR) for mental health-related CER/PCOR. (0)
  - R T4. Compare the effectiveness of research conduct and design strategies aiming to optimize long-term followup, while avoiding attrition bias and avoiding confounding the relationship between interventions and outcomes. (0)
  - R I-1. Longer-term studies are needed to follow individuals involved in various treatments. For the most part we only study the impact of treatments over short periods. (0)
  - R I-2. In order to determine the benefits of early interventions in SMI in terms of avoided disability and distress, it is imperative that investigations be funded and conducted over long periods of followup. (0)
  - R I-7. Long-term study designs need to consider potential confounding factors that may “wash out” the effect of the intervention (e.g., shifts in public mental health services, managed care penetration, hospital lengths of stay). These factors can be taken into consideration but require that a sizeable sample be present at the start. (0)
  - R I-9. Due to predictable attrition and various potential confounders, sizeable samples are needed for long-term studies to adequately maintain sufficient power for longitudinal conclusions to be drawn. (0)
  - R T5. Compare different approaches to analyzing long-term trial or observational data, such as using illness trajectories vs. typical measures (e.g., initial and follow-up measures of symptoms and level of functioning). (0)
  - R I-3. Research is biased toward using randomized controlled trials as the gold standard, but this may not be the most appropriate model for mental health research focused on patient-centered outcomes. (0)
  - R 1-4. The framework of how care is delivered and research is conducted is based on a short-term model and may not be applicable to chronic diseases or consistent with the nature of SMI. (0)
  - R I-8. In long-term studies, do diagnostic shifts over time introduce significant confounding? (0)
  - R NT4. Need to develop longer-term study(ies) with continuous treatment. Must analyze data like an observational study, and could study Medicaid data and population. (0)
  - R I-24. Specific and nonspecific strategies. (0)
  - PC Idea1. Need to consider long-term nature of SMI disorders, with relapsing/episodic course. (0)
5. Identify disparities and reasons for disparities and reevaluate the framework for researching disparities. (40) *
  - D 28. Reasons for disparity. (14)
    i. Barriers and access issues.
    ii. Clinical.
    iii. Systems.
    iv. Institutional racism.
  - D 57. How to find research collaborative in community-based organizations? (9)
  - D 38. Outcomes of interest? (8)
    i. Who/what is successful?
    ii. Improved outcomes.
    iii. Quality of life.
    iv. Patient satisfaction/happiness.
    v. Customer services.
  - R I-16. There is a need for more research focused on specific racial and ethnic communities and any research focus should include outcomes specific to these populations. Must address the overall lack of evidence-based practice inclusion of racial and ethnic communities as participants in research. (4)
    i. SH Note: Mental health research seems far behind. Needs major overhaul.
    ii. SH Note: Data clean-up: Must define Latino population more clearly (Mexican, Puerto Rican, South American). Include data such as: (1) years in the United States, (2) language, (3) acculturation.
  - D 46. Need to document disparity in public and private settings. (2)
  - D 52. How to identify community-defined evidence? (2)
  - D 24. Reevaluate framework for subpopulation research—identify why current research isn't answering the questions. (1)
    i. SH Note: To break through the current status quo on resolving disparities, perhaps we need to experiment with a different funding mechanism, asking communities to initiate research studies and having community representatives act as research review panels.
  - D Idea2. There is a need to look at the causes and risk factors for lack of services to people with limited English-language skills. (0)
  - D 48. Need to understand how to get data from a patient perspective. (0)
  - D 51. How to support community infrastructure? (0)
  - D 54. How to develop workforce diversity? (0)
  - D 55. How to get grassroots organizations to communicate data needs to the community? (0)
  - D 56. How to use grassroots organizations to translate intervention in culturally competent ways? (0)
  - D 29. What are the outcomes of interest from the specific disparities? (0)
  - D 50. What is working in communities; how to get better outcomes? (0)
  - D 53. What are best practices in the community? (0)
  - D 30. What are the cost implications when accounting for vs. not accounting for race/ethnicity? (0)
  - D 49. What are the disparities within communities? (0)
  - PC 40. Importance of disaggregating data for subpopulations to identify disparities. (0)
6. Role of the therapeutic relationship. (40) *
  - PC 38. Focus on relationship between client and provider as central to effectiveness research. Therapeutic alliance accounts for a large degree of variance in psychotherapy treatment outcome(s). Measurement of this factor should be part of evaluation of treatment outcomes. (20)
  - R Idea12. What are the features of health professionals that support the development of a “continuous healing relationship”? If factors associated with better patient outcomes could be identified (perhaps using qualitative research methods), we may then be able to develop approaches to training professionals to be more effective in their clinical interactions. (10)
    i. SH Note: What are the qualities of the person or organization providing the care? Does this have implications regarding outcomes?
    ii. SH Note: Need Accreditation Council for Graduate Medical Education-approved update training that is consistent with the current/future community practice.
  - R NT12. Study how individual characteristics are the biggest factors in whether one gets a disease, and how well one does; what individual factors predict onset; and how one does after onset. Also, include studying the therapeutic relationship as predictor of patient. (7)
    i. SH Note: Education/Medicaid database—but what if those functions/treatments/episodes of care are not applicable to the majority of people with mental illness who are not treated.
  - D 44. Comparing outcomes for English, non-English, and non-standard English speakers. (2)
  - PC 6. Compare the effectiveness of a recovery-based model of care to usual care on long-term functional outcomes in patients with SMI. This model could include a continuous therapeutic relationship with a coach, therapist, or other clinician. (1)
  - PC Idea2. A continuous healing relationship is a beneficial core feature of care. (0)
  - D 32. Impact on outcomes for patients utilizing community leaders as providers (clergy, folk healers, traditional healers). (0)
  - PC 44. Relationship of provider—disparities. (0)
7. Strategies to personalize/individualize treatment. (39)
  - D 3. Compare the effectiveness of psychotropic medications in subgroups of patients (e.g., age, race, and common comorbidities) to identify variation in patient responses and predictors of response that could inform the selection of treatments. (13)
    i. SH Note: Are providers informed about ethnic differences in responses to medications? (Ethno-psychopharmacology)
    ii. SH Note: Much is known about this. The variance by race is less than the variance within racial groups, so personalized care is essential.
  - D 40. Individualized treatment vs. one-size-fits-all. (12)
    i. Consideration of specific cultural characteristics.
    ii. Interventions/systems that do consider these vs. those that don't.
    iii. SH Note: To what degree do we value indigenous ways of knowing and healing methods?
  - PC 41. Study relationship of ethnicity and intervention and outcome. (8)
  - R I-11. Integrating decision analysis into a comparative effectiveness trial could lead to interesting approaches to improving outcomes through individualizing care. (4)
  - PC 8. Compare the effectiveness of various strategies to best individualize pharmacologic therapy for people with SMI, including how to most efficiently find a tolerable regimen. (1)
  - PC 37. Large database for individualized treatments. (1)
  - D 7. Compare the effectiveness of using biomarkers to guide psychotropic medication therapy with usual care for people with SMI. This could include comparing pharmacogenomic-guided therapy with usual care. (0)
  - PC 15. Compare the effectiveness of targeting specific recovery-related interventions to individual's (or families') goals and wishes. (0)
8. Treatment approaches to avoid early mortality and morbidity. (34) *
  - PC 1. Compare the effectiveness of different treatment approaches in avoiding early mortality and comorbidity among people with SMI. For example, this could include integrating mental health care and primary care, improving consumer self-care, or a combination of integration and self-care. This could also include comparing various types of integrated care, such as co-locating mental health providers in primary care vs. primary care providers in mental health treatment settings. (16)
  - PC Idea4. Consider adding warnings/disclaimers on the medication circular that every patient receives. (6)
  - PC Idea3. Pharmaceutical companies could establish “Product Learning Centers” with the purpose of providing specific face-to-face support group meetings for the SMI community, patients, and their families to educate them about potential harms of medications, such as weight gain and the increased risk of diabetes, heart disease, and other health problems that may result from obesity. (4)
  - D 37. Medications alone vs. medications plus psychosocial treatments in underserved or specific groups. (4)
  - D 11. Compare the effectiveness of different approaches to prevent early mortality for subgroups of people with SMI, including racial, ethnic, and cultural subgroups. (2)
  - PC 28. Compare the effectiveness of interventions (including pharmacologic and nonpharmacologic) to prevent early mortality, including suicide, for people with SMI. (1)
  - D 25. Pregnant women as a subpopulation. (1)
  - PC 36. Compare versions of assertive community treatment (ACT). (0)
    i. SH Note: Look into a client-created alternative to ACT-PACE from the National Empowerment Center (Dan Fisher, MD, PhD, Executive Director).
  - PC 19. Compare the effectiveness of older (and less expensive) vs. newer psychotropic medications used at typical doses on long-term outcomes and costs (direct and indirect) of treatment. A detailed analysis of the inherent study biases in such trials as part of a comparative effectiveness review would be a useful addition to the knowledge base. (0)
  - PC 13. Compare the effectiveness of combinations of psychotropic pharmacologic interventions for controlling SMI as well as for controlling a specific individual's other symptoms. (0)
  - D 34. Polypharmacy: effectiveness or lack thereof within specific racial/ethnic groups. (0)
  - PC 16. Given the side effects of medications and many patients' reluctance to consider medications (possibly related to negative and sometimes devastating side effects such as tardive dyskinesia), compare the effectiveness of bundled programs of antipsychotic medications with various bundled psychosocial interventions (partial treatment, supported work, care programs designed by empowerment-oriented consumer groups, residential care, family intervention) on quality of life, patient satisfaction, symptom course, health outcomes, and psychosocial outcomes. (0)
  - R I-15. There is concern about the problematic relationship and practices of the pharmaceutical industry in mental health treatment and intervention. (0)
9. Role of the psychiatric hospital, lengths of stay, and transition support services after discharge. (29) *
  - D 9. For individuals with SMI (with similar diagnoses and disease severity) and repeated hospital admissions, compare the effectiveness of different lengths of hospitalization on readmission rates, relapse, and remission. This could include assessing the circumstances that are best suited for long-term hospitalization to be more effective and specific interventions that enhance the effectiveness of long-term hospitalization. (10)
  - PC 20. Compare the effectiveness of different lengths of hospital stay (e.g., ultra-short stays of 1–4 days vs. longer stays of 7–10 days) on addressing various outcomes, including readmission rate in patients with SMI with similar diagnoses, demographics, and disease severity. (8)
    i. SH Note: Include readmissions because mental health diagnosis & mental health impact on physical health.
  - PC 21. Compare the effectiveness of different lengths of hospital stay on addressing various outcomes, including whether the individual and involved family felt that the factors prompting the admission were adequately addressed, whether the individual and involved family felt that the stay was sufficient to address safety and dangerousness concerns, and whether differences in length of stay influence other variables (e.g., satisfaction with care, adherence, insight into illness) in SMI patients with similar diagnoses and disease severity. In this comparison, consider whether factors such as housing stability or social support network confound the relationship between length of stay and readmission rates. (7)
    i. SH Note: Include readmissions because mental health diagnosis & mental health impact on physical health.
    ii. SH Note: As part of examining the role of inpatient hospitalization, examine: (1) the role of step-down transition in community-based settings and (2) the role of alternatives to inpatient care (caring (?) residential, home-based, intensive outpatient).
  - D 23. Compare the effectiveness of different approaches to support transitions after hospital discharge for subgroups of people with SMI, including racial, ethnic, and cultural subgroups. (4)
  - PC 23. Compare the effectiveness of diverse models of transition support services for people with complex health care needs (e.g., the elderly, homeless, and mentally challenged) after hospital discharge on various outcomes, including readmission rates. (0)
  - PC 30. Compare the effectiveness of management strategies (e.g., inpatient psychiatric hospitalization, crisis residential services, extended observation, partial hospitalization, intensive outpatient care) for people with SMI and various potential indications for hospital admission, including following a suicide attempt. (0)
  - PC 26. Compare the effectiveness of various characteristics, quality, and intensity of care, along with duration of care (i.e., length of hospital stay), on outcomes for people with SMI. (0)
    i. SH Note: The unintended consequences of involuntary treatment. The fear of forced treatment actually keeps people from seeking mental health treatment.
  - R I-14. The specifics of treatment are important. Concern with treating length of stay as a black box. SMI outcomes are based on differences within similar treatment modalities and systems (vs. between different modalities). (0)
10. Retooling universities and education. (27)
  - R NT13. Need innovative incentives to address the discrepancy between university- based education and approach/methods that work. (27)
11. Strategies to increase adherence to evidence-based guidelines and treatment regimens. (27) *
  - PC 10. Compare the effectiveness of alternative redesign strategies—such as using multidisciplinary treatment, electronic health records, decision support capabilities, and personal health records—for increasing health professionals' compliance with evidence-based guidelines, increasing patients' adherence to guideline-based regimens, and improving continuity of care and communication. (17)
  - R NT5. Must explore the role of (the future role) of EMRs for everyone and how the relationships among structure, process, and outcomes in EMRs might contribute to doing new mental health research. (5)
  - PC 35. Compare technological interventions with standard care. (3)
  - PC 24. Compare the effectiveness of strategies for enhancing adherence to medication regimens for people with SMI. (1)
  - PC 34. Preference sensitive care vs. usual care on adherence and other outcomes of importance. (1)
12. Correctional programs and interventions for people involved with the criminal justice system. (26) *
  - D 21. Compare the effectiveness of evidence-based correctional practices (such as those targeting risk factors for crime, like antisocial attitudes, with cognitive-behavioral techniques) with psychiatric treatment alone for their ability to promote community reentry. (9)
  - D 10. Compare the effectiveness of correctional programs vs. psychiatric treatment alone on outcomes such as community reentry among criminal offenders with mental illness. (7)
  - D 22. For adults with SMI who are involved with the criminal justice system, compare the effectiveness of organized interventions that can prevent re-arrest and re-incarceration. (3)
  - D 13. Compare the effectiveness of various approaches to training the law enforcement workforce to identify and appropriately disposition people with SMI. (2)
  - D 19. For adults with psychotic disorders who are involved with the criminal justice system, compare the effectiveness of supported employment and traditional job counseling on job placement, job retention, and criminal recidivism. (2)
  - D 39. Criminal justice population differences within populations and recidivism risk. (1)
  - D 16. For adults with psychotic disorders who are involved with the criminal justice system, compare the effectiveness of crisis intervention teams, mental health courts, and mental health probation or parole on community adjustment, reductions in criminal recidivism, and costs. (1)
  - D 20. For prisoners with psychotic disorders, compare the effectiveness of suspending Medicaid benefits at the time of admission with terminating Medicaid benefits followed by expedited restoration prior to release on time to first mental health service use following release, engagement in services, criminal recidivism, and costs. (1)
  - D 43. Compare psychiatric services with evidence-based interventions (EBI) for recidivism. (0)
  - D 17. For adults with psychotic disorders who are involved with the criminal justice system, compare the effectiveness of forensically adapted intensive case management with forensically adapted assertive community treatment on community adjustment, reductions in criminal recidivism, and costs. (0)
  - D 18. For adults with psychotic disorders who are involved with the criminal justice system, compare the effectiveness of forensically adapted assertive community treatment (FACT) with FACT plus cognitive behavioral therapy for criminogenic thinking on community adjustment, reductions in criminal recidivism, and costs. (0)
  - D Idea1. The interrelationship between the criminal justice system and individuals with SMI is important (e.g., training of criminal justice professionals, care for SMI individuals in the criminal justice system). (0)
  - R I-5. There is a need to include criminal justice perspectives in discussions of mental health research and policy. (0)
13. Interventions for people with comorbid medical illness or substance abuse. (26)
  - D 1. Compare the effectiveness of pharmacologic and nonpharmacologic interventions for people with SMI and comorbid medical illnesses (e.g., diabetes, HIV, and cardiovascular disease). (16)
  - D 27. Compare the effectiveness of treating mental illness and comorbidities on both mental and physical health. (8)
  - D 2. Compare the effectiveness of interventions or programs for people with both substance abuse and SMI (multiple diagnoses/comorbidities) on outcomes for both diagnoses. (2)
  - D 5. Compare the effectiveness of treatment interventions for SMI in people with coexisting symptoms, such as anxiety, insomnia, irritability, pain, or somatization. (0)
  - D 6. Compare the effectiveness of strategies to screen for and treat sleep apnea in people with SMI. (0)
  - D 8. Compare the effectiveness of antipsychotic medications with and without concurrent medical marijuana in the treatment of psychotic patients who are already prone to marijuana use. (0)
14. Prevention, early identification, trajectories, and developmental perspective. (25) *
  - R NT9. Need frameworks that address prevention strategies/mental health research that also includes a developmental perspective/trajectory (e.g., catch at first episode). (18)
  - D 42. Look at psychosocial stressors that precipitate mood disorders. (4)
  - PC 5. Compare the effectiveness of strategies to identify and treat SMI early in the course of illness on long-term outcomes, including quality of life. (3)
  - R NT22. Expand understanding that prevention is not just about prevention, but is also about delaying the onset of the condition. (0)
15. Dissemination and implementation. (23) *
  - PC 32. Need for more work on implementation science. (19)
    i. SH Note: Plus more work on science in mental health—so much remains unknown.
  - R T1. Compare the effectiveness of strategies to disseminate and implement research findings and new discoveries into community practice to foster evidence-based, state- of-the-art treatment. (4)
    i. SH Note: How do we approach communities? Does this affect outcomes?
  - R T2. Compare the effectiveness of strategies to advance evidence-based practices using dissemination and demonstration projects. (0)
16. Reducing barriers and improving access. (13)
  - PC 11. Compare the effectiveness of sustainable interventions to reduce barriers to access for mental health services, including transportation, financial barriers, and insurance coverage barriers. For example, for those with clearly documented SMI, intervention groups (vs. bureaucracy-as-usual groups) could have streamlined access to Medicaid including access to essential medication while benefits are pending, meeting with a Medicaid worker at their home or their follow-up care site rather than at social services, automatic Medicaid renewal rather than having to reregister, ability to reenter the workforce part-time without losing key benefits, etc. What about changes in benefits packages to enhance health promotion (e.g., giving additional money for food stamps but designating that a certain percentage can only be used for fresh fruits and vegetables)? (4)
  - PC 14. Compare the effectiveness of strategies to obtain regular dental care for people with SMI on outcomes such as quality of life and physical well-being. (3)
  - D 15. Compare the effectiveness of strategies to reduce the barriers to accessing effective programs and to sustaining recovery for underserved populations, such as homeless people with SMI. (3)
  - D 14. Compare the effectiveness of health technology and telehealth to improve access to and coordination of care, especially for Americans in remote areas or in underserved populations. (2)
  - D 4. Compare the effectiveness of interventions to reduce barriers and improve access to care for people with SMI living in rural locations. (1)
17. Mental health policy. (11)
  - R T6. Compare the effectiveness of various policy practices in mental health on outcomes including cost-effectiveness and reach. (7)
  - R I-13. There is a need to establish national, regional, and/or state legal panels and/or watchdog agencies to ensure dissemination (and enforcement, if made law) of information and legislation related to persons with SMI. (2)
  - D 31. Receipt of information by families—patient outcomes. (1)
  - D 60. Medical information that is not made available to family members can grossly affect the quality of life of people with SMI as well as any future medical treatments (including physical health and mental health, emotional health). (1)
  - D 47. Need watchdog agency. (0)
18. Modifiable factors: tobacco, exercise, and nutrition. (10)
  - D 12. Compare the effectiveness of various tobacco cessation strategies for individuals with SMI and tobacco addiction. (6)
  - PC 25. Compare the effectiveness of interventions targeting modifiable factors such as daily caloric intake, physical exercise, mental exercise, and nutrition on health outcomes for people with SMI. (4)
19. Alternatives to force or involuntary approaches. (9)
  - PC 27. Compare the effectiveness of alternatives to interventions using force or involuntary approaches (e.g., seclusion and restraint) in people with SMI. (9)
20. Providing housing or social support. (9)
  - PC 4. Compare the effectiveness of different strategies to provide stable housing for people with SMI on mental health outcomes. (6)
  - PC 22. Compare the effectiveness of various approaches to providing housing or social support on outcomes, such as readmission rates. (3)
  - PC 9. Compare the effectiveness of various strategies to assist people with SMI with achieving normative success in education, relationships, employment, and housing on mental health outcomes including quality of life. This could be to assist with meeting normal developmental challenges or early adulthood or during later stages of life. (0)
    i. SH Note: Include outcomes like school attendance, missed work, etc.
21. Strategies to reduce stigma, prejudice, and discrimination. (3) *
  - PC 29. Compare the effectiveness of strategies to reduce stigma, prejudice, and discrimination against people with SMI and to encourage their social inclusion. (3)