# Issues Exploration Forum Stakeholder Participants

Name | Affiliation | Title
Buck, Jeffrey A., PhD | Center for Mental Health Services Substance Abuse and Mental Health Services Administration | Chief, Survey Analysis and Financing
Collins, Chris, MSW | NC Dept. of Health and Human Services | Deputy Director, Office of Rural Health and Community Care; Asst. Director, Managed Care, Division of Medical Assistance
Crystal, Stephen, PhD | Center for Health Services Research on Pharmacotherapy, Chronic Disease Management, and Outcomes and Center for Education and Research on Mental Health Therapeutics | Board of Governors; Professor; Director, Research Professor and Chair, Division on Aging
Crystal, Stephen, PhD | Institute for Health, Health Care Policy, and Aging Research Rutgers University | Associate Director
Cuerdon, Timothy T., PhD | Office of Research, Development and Information, Centers for Medicare & Medicaid Services | Senior Advisor, Research and Evaluation Group
Davis, King, PhD, MSW | University of Texas at Austin School of Social Work | Professor and the Robert Lee Sutherland Chair in Mental Health and Social Policy
Dixon, Lisa, MD, MPH | Veterans Administration (VA) Capitol Health Care Network Mental Illness Research, Education and Clinical Center (MIRECC) | Deputy Director and Assoc. Director of Research; Director, Division of Health Services Research
Dixon, Lisa, MD, MPH | University of Maryland School of Medicine | Professor
Duckworth, Kenneth, MD | National Alliance on Mental Illness | Medical Director
Fochtmann, Laura J., MD | American Psychiatric Association | Medical Editor, Practice Guidelines
Fochtmann, Laura J., MD | Stony Brook University Medical Center | Professor of Psychiatry and Behavioral Sciences
Tisamarie B. Sherry | Office of Disability, Aging, and Long-term Care Policy | Graduate Student Intern
Tisamarie B. Sherry, Representing: Frank, Richard G., PhD | Office of Disability, Aging, and Long-term Care Policy | Deputy Asst. Secretary for Planning & Evaluation
Galper, Daniel, PhD | American Psychological Association | Director, Practice Research & Policy
Gerhard, Tobias, PhD | Rutgers University | Asst. Professor, Institute for Health, Health Care Policy and Aging Research
Goldman, Howard H., MD, PhD | University of Maryland School of Medicine | Professor of Psychiatry
Gonzales, Junius J., MD, MBA | University of South Florida | Dean, College of Behavioral & Community Sciences
Gray, Carrie, MBA | WI Dept. of Health Services | Pharmacy Policy/Program Analyst
Guerrero, Rachel G., MSW, LCSW | CA State Dept. of Mental Health | Consultant (formerly Chief), Office of Multicultural Services
Hennessy, Kevin, PhD | Substance Abuse and Mental Health Services Administration | Senior Advisor, Science to Service Coordinator, Office of Applied Studies
Hogan, Michael F., PhD | NY State Office of Mental Health | Commissioner
Jordan-Randolph, Gayle, MD | Spring Grove Hospital Center | Clinical Director, Mental Hygiene Administration
King, Jeff, PhD | Western Washington University | Director, Center for Cross Cultural Psychology
Laughren, Thomas P., MD | Food and Drug Administration | Director, Division of Psychiatry Products
McQuistion, Hunter, MD | The St. Luke's & Roosevelt Hospitals | Director, Division of Outpatient and Community Psychiatry, Dept. of Psychiatry and Behavioral Health
McQuistion, Hunter, MD | Columbia University College of Physicians & Surgeons | Assoc. Clinical Professor of Psychiatry
McQuistion, Hunter, MD | American Association of Community Psychiatrists | President
Mordecai, Don J., MD | The Permanente Medical Group | Director of Mental Health and Chemical Dependency Services, Chair, Chiefs of Psychiatry
Mościcki, Eve K., ScD, MPH | American Psychiatric Institute for Research and Education | Director, Practice Research Network
Nordal, Katherine C., PhD | American Psychological Association | Executive Director for Professional Practice
Perou, Ruth, PhD | Centers for Disease Control and Prevention | Child Development Studies Team Leader, Division of Human Development and Disability
Pincus, Harold A., MD | Columbia University | Professor and Vice Chair, Dept. of Psychiatry, College of Physicians & Surgeons Co-Director, Irving Institute for Clinical and Translational Research
Pincus, Harold A., MD | New York-Presbyterian Hospital | Director of Quality and Outcomes Research
Pincus, Harold A., MD | RAND Corporation | Senior Scientist
Robinson Beale, Rhonda J., MD | OptumHealth | Chief Medical Officer, OptumHealth Behavioral Solutions
Rupp, Agnes, PhD | National Institute of Mental Health | Senior Research Economist, Chief, Financing & Research Methods Programs
Schraiber, Ron, MA | Los Angeles County Dept. of Mental Health | Mental Health Analyst III, Program Support Bureau
Sharfstein, Steven S., MD | Sheppard and Enoch Pratt Hospital | President and CEO
Shern, David, PhD | Mental Health America | President and CEO
Skeem, Jennifer L., PhD | University of California, Irvine | Professor, Psychology & Social Behavior
Williams, Pluscedia | Healthy African American Families II | Outreach Specialist
Yates, Sharon R. | National Alliance on Mental Illness | Member, Board of Directors, NAMI Urban LA
Young, Alexander S., MD, MSHS | VA Desert Pacific MIRECC | Director, Health Services Unit
| University of California, Los Angeles | Professor, Dept. of Psychiatry
Zarin, Deborah, MD | Clinicaltrials.gov | Director
Zerzan, Judy, MD, MPH | CO Dept. of Health Care Policy and Financing | Medical Director, Medical & Child Health Plan Plus Program Administration Office