# Appendixes

Appendix A Issues Exploration Forum Stakeholder Participants

Appendix B Detailed Prioritized List of Topics