# Results and Case Studies

## Step 1 Focused Literature Review

We conducted comprehensive literature reviews in two broad areas: evaluation of surrogate endpoints and the value and use of animal models in translational research. Both searches encompass the publication dates between 2000 and 2009, with additional references found before and after those dates through reference and citation searches. 125 articles on animal models were reviewed, 133 on surrogate markers and 24 on evidential grading systems. 93 of the articles on ‘ animal models were summarized in an annotated bibliography, as were 103 of the articles on certain points. All of these articles were mapped into a preliminary version of a conceptual framework because the modified framework had not been developed when this was originally done. These bibliographies can be found in Appendices A and B.

## Step 2 Development of Draft Framework

On the basis of preliminary reading in each of the domains described previously, the following draft framework was proposed. This was both discussed at the invited workshop, and used for the mapping exercise in the annotated bibliography. This draft framework was as follows:

Strength of evidence for:

1. Existence of pathway.
2. Existence of pathway in humans.
3. Completeness of pathway.
4. Alternate, competing or compensatory pathways
5. Similarity to other interventions/mechanisms with known clinical effects
6. Adverse event mechanisms

## Step 3 Workshop With Technical Experts

We identified technical experts representing a variety of disciplines relevant to the development of this framework. These included translational medicine, biomarker development, philosophy, evidence-based medicine, toxicology and animal research. The proceedings of the workshop are presented in Appendix C.

The discussion in the workshop covered a very broad territory, reflecting the range of expertise among the participants. Each participant presented an example from their own domain of work of the use of mechanistic information in the development, evaluation, or prediction of the efficacy of a therapy. These perspectives then informed a conversation focused specifically on the components of the framework, as well as providing potential examples for its application. The discussions in this workshop were quite rich, going far beyond the issue of the framework itself. However, both the examples and ensuing discussion of the framework highlighted the following potential weaknesses in the draft framework as proposed:

1. Virtually all pathways represent biologic mechanisms that are incompletely known.
2. Most therapies are developed based on partial knowledge of mechanisms, and attempt to affect just one step in a pathway, typically called a “target”.
3. Most clinical effects are mediated through multiple pathways.
4. Both the quality and relevance to humans of experiments in animals are widely recognized as deeply problematic, yet still important to refine or winnow the list of candidate interventions.
5. Experimentation in animals serves many purposes other than documentation of whole organism responses. The use of transgenic organisms, and other genetically manipulated animals makes them occasionally excellent experimental models for specific therapeutic effects.

As a result of these observations plus discussion in the workshop along with further literature searching, the originally proposed framework was modified as described in the next section.

## Step 4 Development of Framework

To be maximally useful, an evidential framework for mechanistic knowledge must be applicable to all forms of interventions in humans to prevent or treat disease. That requires a high degree of generality for the overall structure, with elements that are customizable for particularly contexts, e.g., drugs, devices or behavioral interventions. Second, it should have the irreducible minimum of elements, capturing only those that are absolutely essential for the task. Finally, the potential application and context in which this framework is expected to be used must be clear. The main domains of application are in those settings where empirical information directly linking intervention to human outcome is absent or weak, such as typically occurs in early phase clinical testing or technological development, but also arises in many other contexts, listed in Table 1.

The main approach and the revision of the framework was therefore to consider what were the minimal requirements for what could be called a biologic mechanism. The existence of a “target,” a single intermediate step in the causal pathway between the intervention and the outcome, is central to the definition of a biologic mechanism. The existence of such a step is a minimal, necessary condition for mechanistic knowledge to be informative about the intervention-outcome relationship. Without this step, the totality of the evidence is from the empirically observed relationship between intervention and outcome, which by definition is not mechanistic. Therefore, this framework does not include linkages that directly connect an intervention and an outcome, which represent evidence that is important, but it is not “mechanistic”. A target is defined here as a necessary step in a sufficient pathway, or a component of a sufficient cause.

The use of the target connects this framework to the development of therapeutic interventions, wherein a molecular or mechanistic target for an intervention is identified. This target can take a physical form, such as a protein binding site or metabolic process, or it could be a psychological or even sociological state that is part of a proposed mechanism. Any component of a mechanism can in theory be a target for intervention.

These considerations lead to the development of an alternative framework that reflected the minimally sufficient set of conditions and categories for evidential measurement and perhaps not coincidentally, the developmental processes of therapeutics as well. The language of “pathways” in the original draft framework was too limiting, in that it is rare that all steps in a given pathway are understood, and even when they are, such as in the coagulation cascade, typically only one is targeted with a particular agent. Thus the concept of mechanism must involve at least one intermediate step, with an attendant theory about how that step (here called the target) is part of the causal chain. The revised framework was as follows:

Strength of evidence for the:

1. Intervention’s target effect in nonhuman models.
2. Clinical impact of target effect in nonhuman models.
3. Predictive power of nonhuman model for an effect in humans
  3t The predictive power of the target effect model
  3c The predictive power of the clinical effect model
4. Intervention’s target effect in human disease states.
5. Clinical impact of the target effect in human disease states.

This framework is demonstrated graphically in Figure 1 below:

Figure 1 Schematic of mechanistic framework model

This figure diagrams the relationship between components of mechanistic information in nonhuman models and the same in humans. Arrows, labeled “1” and “4” depict the relationship between Intervention and Target biological effect in nonhuman and human models respectively. An arrow labeled “3t” marks the predictive power of the relationship in nonhuman models for predicting the same relationship in human models. Arrows labeled “2” and “5” depict the subsequent relationship between Target Biological effect and Clinical effect in nonhuman and human models respectively. An arrow labeled “3c” marks the predictive power of the relationship in nonhuman models for predicting the relationship in human models.

This is the minimally sufficient series of steps necessary for such a framework, and has sufficient generality to apply to virtually all types of interventions. It represents a “chain of evidence” that is often used in other evidential frameworks and risk assessment models to assess cumulative evidential strength. This shows how the evidence in humans trumps that in nonhuman models, in that the nonhuman evidence requires a “translation” step (3t or 3c), so that the stronger the human evidence, the less necessary that from the indirect sources. The weaker the human evidence, the more the linkages from 1, 2, and 3 are critical to the inference. Each one of these dimensions has a set of distinctive characteristics that need to be assessed, which will be discussed below.

### Intervention’s Target Effect in Nonhuman Models

All interventions and biologic processes work though at least one intermediate target step that is necessary but not sufficient to produce a biologic effect. A series of such steps, mechanistically linked, is called a “pathway.” Most therapies act on, or are designed to act on, just one key step in that pathway through a “target”. Anticoagulants typically interfere with the coagulation cascade at an identifiable point or points. If a proposed anticoagulant had no demonstrable effect on any step in that cascade, this would serve as strong mechanistic evidence against a clinical effect. If the key target step is purely theoretical, never having been demonstrated in a biologic system, any claim based on such a mechanism would have negligible weight. Occasionally, this step is not consistent with known physical principles. This might include homeopathic remedies with no detectable agent in the preparation, a claimed radiation effect when it can be demonstrated that the target tissue receives no exposure or a vaccine that is not antigenic.

This key step often defines the class of intervention of drug, for example, calcium channel blockers, proton-pump inhibitor, tyrosine kinase inhibitors, cardiac bypass procedure, etc. While other details of mechanism typically differ somewhat among interventions in a class, they all have some form of the key step in common, with either the identical target effect, or effect on the same pathway in which the target exists. The key elements of evidential quality related to this step are as follows:

1. Evidence that it is physically possible for the intervention to exert a physical effect through the target (e.g., absorption, PK, PD for drugs, ability to place a cardiac stent in a narrowed artery).
2. Evidence for the validity of the measure of the effect on the target. (e.g., that the assay that confirms receptor site blockage is an accurate measure of that blockage.)
3. Evidence that intervention in question has desired impact on the measure of target effect.

Embedded within each of the above evidentiary requirements are a set of components that are intervention or target specific, including components of good study design, and research on related interventions and targets. It includes both the qualitative considerations and the quantitative strength of relationships. The evidential framework for biomarker validation described by Altar (Altar et al., 2008; Altar, 2008) contains most of the above elements, including the explicit mention of the existence of a theory, which is presupposed here.

### Clinical Impact of Target Effect in Nonhuman Models

This next step in the evidence framework involves linking the effect on the target to some whole-organism impact that parallels a human clinical outcome. The strength of evidence for this step includes:

- Evidence for the analytic validity of the clinical impact measure. (It must be recognized that it increases the odds of success by several orders of magnitude, leaving the clinical evaluation process to increase it yet further.)
- Evidence relating target effect to measure of clinical impact.

This dimension concerns the relationship between the target effect and the clinical outcome. This can include evidence both with and without the intervention. For example, if there are ways to induce the target effect without the intervention, this can serve as supporting evidence for this step. Similarly, among groups who experienced intervention, supporting evidence would be a differential clinical effect among those who had a demonstrable target effects versus those who had not. For example, if we were examining an agent that improve surgical mortality by decreasing operative blood loss, supportive evidence for this step could include experiments showing such improved mortality when blood loss was reduced by means other than the agent under study. If, on the other hand, all subjects were given the agent under study, and those who had reduced blood loss had lower operative mortality than those who did not, all other factors being equal, this also would support mechanism. It is important to note that unless the target step itself can be randomized, which is often not the case, this evidence will be derived from observational designs. If the intervention were randomly applied to one group and not another, and the clinical outcome observed, such direct empirical evidence would not constitute mechanistic evidence per se, although the demonstration that a difference in outcome correlated with the (nonrandom) difference in blood loss, the mechanism would be supported. Conversely, if blood loss in the two groups was identical, this would diminish the plausibility of conclusions derived from the direct empirical evidence, and precipitate a search for alternative mechanisms of clinical benefit.

A major question in nonhuman models is how to measure a clinical endpoint. By clinical endpoint is meant an outcome in a whole organism that in itself is likely to have a health benefit if experienced in humans. Such measures can include mortality, functional impairment, wasting and behavioral changes. Outcomes such as shrinkage of a tumor xenograft are more controversial, as such an effect in a human might be regarded as a surrogate outcome. This would depend on the specifics of the disease and therapy, and perhaps on the magnitude of the effect (e.g., complete remission versus modest reductions).

There is a varying language that is used in the literature for this step. In much of the biomarker and translational medicine literature establishing a clinical correlate for a change in the biomarker is called “qualification,” a step often preceded by “analytic validation” of the biomarker. (Altar, 2008; Alymani et al., 2010) However, in the surrogate endpoint literature this is frequently referred to as “clinical validation,” or simply “validation.” (Wagner, 2002; Kluft, 2004; Buyse et al., 2010) We will employ the latter usage but note that this refers to the same phenomenon as biomarker “qualification.” This dimension does not include the relevance of the outcome in the nonhuman model to a similar outcome in humans; that is captured in the next dimension.

As in the previous dimension, embedded within these evidentiary requirements are a set of components that are intervention or target independent, including components of good study design, and research on related interventions and targets. It includes both the qualitative considerations and the quantitative strength of relationships. Conventional measures of study quality apply; blinding of outcome assessment, use of multiple models in multiple laboratories, consistency of multiple related endpoints. Because many of these designs will be observational, standard criteria (e.g., Hill’s) for inferring a causal relationship from observational evidence can apply. If it is possible to induce the target effect through randomization, or if this can be achieved through mendelian randomization, the evidence is correspondingly stronger. (Altar, 2008; Alymani et al., 2010; Ransohoff, 2007, 2009)

### Predictive Power of Nonhuman Model for an Effect in Humans

This dimension concerns the generalizability of evidence pertaining to an intervention’s mechanism of action. For this dimension to provide evidential weight there must be some basis for the extrapolation from animal to human based on mechanistic considerations. This is the “translation” step, and can be divided into the translation of the target effect (3t) and clinical effect (3c). Either could be based on a mechanistic basis for the analogy (i.e., all drugs with similar mechanism of action showed a relationship between animal and human effects). Such an analogy represents a chain of reasoning going back to the mechanism of action in at least one member of the class.

One of the concerns about the validity of animal to human extrapolation concerns whether the disease state in animals is produced by the same pathophysiologic processes as those of humans. These differences often arise from a poor understanding of these processes in humans, or of an inability to create or observe a parallel condition in nonhuman models. If the mechanisms of disease in humans are poorly understood it is very difficult to know whether the relevant components of that mechanism are adequately represented in nonhuman models. In addition, it can be extraordinarily difficult to mimic in nonhuman models those ancillary factors associated with human disease states that often mediate the effect of therapy, such as comorbidities, tolerance of treatment, and cotreatment.

In the end, the relevance of nonhuman (usually animal) models to humans is among the most difficult steps in the framework to satisfy or even to assess. The failure of animal models to reliably predict effects in humans has been widely documented (Alonso de Lecinana et al., 2001; 't Hart et al., 2004; DiBernardo and Cudkowicz, 2006; Benatar, 2007; Bolton, 2007; Crossley et al., 2008; Ayhan et al., 2009; Bracken, 2009). Appendix A, the annotated bibliography of literature on animal experimentation, documents the extent and causes of this issue. As noted previously, the failure to reliably predict does not mean that animal experiments do not provide substantial evidence; it merely means that they do not raise the probability high enough upon which to make clinical decisions. This predictive power varies widely by condition and treatment, but as noted previously, typically runs in the 5 percent to 20 percent range. Factors that have been described to diminish this predictive value include:

- Animal model for disease does not mimic human pathophysiology
- Design deficiencies in animal studies (e.g., related to randomization, allocation concealment and blinded outcome assessment, replication in multiple labs; Macleod et al., 2005)
- Uniformity of animal models not reflecting human phenotypic or genotypic variability.
- Different PK and PD properties in animals, improper dosing
- Differences in side effects, toxicity and drug interactions.
- Endpoints not mirroring human clinical endpoints
- Nonvalidated outcome measures

### Target Effect in Human Disease States

The measure of the target effect is a biomarker. Therefore all of the factors that affect biomarker qualification, short of correlation with disease outcomes, contribute to evidence for this dimension. Evidence that the intervention can act at target site (e.g., absorption, PK/PD for drugs) is a precondition for creating a target effect. The evidence that the intervention is actually affect the target therefore requires:

- Validity of a measure of the target.
- Validity of measure of presence of intervention at target.
- Validity of measure of biologic effect on target.
- Evidence that intervention has desired impact on target effect measure.

The validity of the measures of each component of this step is a precondition to being able to assess whether a given intervention can alter the target state. When the intervention and target are readily observable, this is can be a trivial determination. However, for many devices and drugs, each of the above steps must be confirmed. For example, in determining whether an implantable cardiac defibrillator (ICD) has a biologic effect, the intervention is an electrical pulse in the myocardium, delivered by the ICD. The “target” is a ventricular arrhythmia, and the desired target effect is the conversion to normal ventricular rhythm. In the ICD case, the measure of intervention is the ICD firing record, the target measure is the intracardiac electrogram stored by the device, which also records the target effect, i.e., the conversion to normal ventricular rhythm. Both of these measures are validated. In this example, near instantaneous conversion is strong evidence of causality, although the proportion that would have continued to the point of physiologic compromise in the absence of the shock would still be uncertain. If there is an observed effect of ICDs on mortality without the devices firing, or without a commensurate number of converted arrhythmias, it becomes difficult to explain how the mortality effect was produced, weakening the evidence for the effect. In situations where causality is not evident in the individual case, the causal relationship must be ascertained in a randomized experiment with the target effect as the outcome. The ICD example also provides a mechanism for an adverse offsetting adverse effect, in that firing of the device in the absence of a target arrhythmia can increase mortality risk, akin to administering a drug where no pharmacologic target is present (Daubert et al., 2008).

In the drug context, the ability for the drug to affect the target step is best ascertained through a randomized or controlled experiment, in which the target effect is measured as a function of the active manipulation of the drug exposure. A detailed example of problems both with measurement and of assessing the target effect is provided in the subsequent Gleevec case study.

### Clinical Impact of Target Effect in Human Disease State

The desiderata of this step in humans is essentially identical to that in nonhuman models, the main difference being that demonstration that the target effect is achievable in humans represent stronger evidence for the clinical effectiveness than does similar demonstration in nonhuman models. This step is equivalent to the biomarker “qualification” or surrogate endpoint “validation,” as noted previously. It is often not possible to use randomization to completely eliminate the potential effect of covariates in determination of this effect. Target effects, which occur in some patients but not others, are typically post randomization events, and as such can require special statistical techniques to derive proper causal inferences (Prentice, 1989; Buyse et al., 2010).

Even with proper experimental design and analysis, the issue of the proper target measure to use to predict clinical effect can loom large. This was seen in the example of epidermal growth factor receptor (EGFR), where, as Taube et al. noted, “Detectable EGFR … appears to correlate with clinical benefit from EGFR inhibitors in some cases but fails to provide predictive information in others. It is unclear whether these differences are due to test methodologies, the biology of the disease being evaluated, or a combination of both.” (Taube et al., 2009) So while the biologic measure of the target may be valid for the purposes of the precursor step, i.e., documenting the target effect, it may not be valid for the purposes of predicting therapeutic benefit. This underscores the criticality of recognizing that the validation of surrogate markers, measured in a specified way, as predictors of clinical impact often cannot be generalized beyond a given therapy, and clinical disease. When one strays beyond this, the evidence supporting this step has less weight.

A common error in the assessment of biomarkers is to fail to distinguish between the meaning of prognostic and predictive targets (Oldenhuis et al., 2008). A prognostic effect is one in which it is shown that a variation in the target, biomarker or surrogate endpoint correlates with a different frequency of a given clinical outcome. It should be stressed that this variation is not in itself a target “effect”, which is rather an active change in the biomarker through intervention. For the assessment of therapeutic effects, the strength of evidence being sought is between this change, induced by the intervention, with clinical outcomes (Fleming and DeMets, 1996).

Finally, attention must be paid to whether the human model being used for this step is in fact one that is an accurate representation of the clinical setting in which the intervention will be applied. Is the target effect being assessed in patients with the disease or in healthy subjects? If in patients, do they have the same spectrum of comorbidities and cotreatments as expected in the clinical setting? Is the severity of disease similar? Is the mode and intensity (or dose) of administration of the intervention similar to the manner in which it will be applied clinically?

## Step 5 Development of Case Studies and Pilot Test of the Framework

Two in depth case studies were developed to see how the conceptual framework being developed would apply to actual examples. The two case studies were of Gleevec for the treatment of chronic myelogenous leukemia and estrogen use in menopausal women for the prevention of heart disease. These case studies were summarized and mapped into the conceptual framework. These two examples are presented below.

### Case Study 1 Gleevec (Imatinib)

#### General Background

We provide first a summary of the knowledge underlying the development of imatinib (Gleevec) for the treatment of chronic myeloid leukemia. Following this, we apply the framework to the facts of that case as they were known when the first human trials were begun.

#### Disease State

Chronic myeloid leukemia (CML) is a disease in which white blood cells are overproduced by the bone marrow. Normally, bone marrow cells called “blasts” mature into several different types of blood cells that have specific roles. CML affects the blasts that develop into white blood cells (granulocytes). The white blood cells do not mature normally, resulting in the proliferation of immature cells and interference with blood and marrow function. Most people with CML have an abnormal chromosome, known as the Philadelphia (Ph) chromosome, in which segments of chromosomes 9 and 22 are fused together. The molecular consequence of this event is the creation of a gene which codes for an abnormal protein called “Bcr-Abl.” This protein functions as a class of enzyme called a “tyrosine kinase,” producing cellular changes that result in CML.

In the majority of CML patients, there are no known hereditary, familial, geographic, ethnic, or economic associations with CML; therefore, the disease is not preventable nor does it appear to be heritable (Alvarez et al., 2007).

#### Therapeutic Mechanisms and Evidence

Gleevec or imatinib (also known as STI571) functions as a specific inhibitor of the Bcr-Abl tyrosine kinase (TK). The active sites of TKs have a binding site for adenosine triphosphate (ATP), which when bound triggers intracellular changes. The principal effect of Gleevec is to block Bcr-Abl’s ATP binding site, thereby inhibiting its enzymatic activity and ability to transform the cell. See Figure 2. Gleevec also induces apoptosis (cell death) of Bcr-Abl–expressing CML cells lines, halting the leukemic process. The target is therefore the Bcr-Abl binding site, and desired effect is to halt the cellular processes leading to carcinogenic transformation that would normally proceed if this enzyme is triggered.

Figure 2 Schematic model for the mechanism of action of Gleevec (imatinib)

This cartoon describes how Gleevec works at the enzyme responsible for CML, an abnormal tyrosine kinase, which binds ATP. The cartoon on the left portrays the binding of ATP to this CML enzyme, which triggers cellular processes leading to carcinogenic transformation, resulting in CML. In the cartoon on the right, Gleevec has bound to the ATP site, blocking ATP activation of the enzyme, causing both cell death and inhibition of CML transformation.

Early preclinical and/or observational studies that lead researchers to explore Gleevec as possible intervention. Gleevec was developed from an observation first made by Nowell and Hungerford in 1960 that CML patients often had an unusually small chromosome (Philadelphia chromosome) not found in other people. Scientists had just learned how to isolate and study human chromosomes using newly developed cytogenetic techniques (the microscopic examination of genetic components of the cell, including chromosomes, genes, and gene products, using slides and stains).

At that point, the field theory of tumor development (i.e., the theory that neoplasms arose from many cells in a tissue made susceptible by exposure to carcinogenic agents) was still widely believed. It was also a time when most investigators did not think that tumors were caused by genetic mutations. Per Nowell (Nowell, 2007, p. 2035): “This might, in part, have been a reflection of the hope, more emotional than scientific, that tumors did not arise from structural changes in the genome because if this was the case, they would not be easy to reverse and treat.”

It was not until the 1970s that improving cytogenetic techniques and other methods were finally developed that generated more specific evidence at the level of individual chromosomes (implicating chromosomes 9 and 22 in CML), and ultimately led to the development of molecular techniques that permitted the identification of the specific genes altered not only in CML but in many hematopoietic and solid tumors.

Additional insight into the pathogenesis of CML came from studies (in mice) of transforming retroviruses. The transforming protein of this virus, v-Abl, was shown to be a tyrosine kinase (TK). The Bcr-Abl protein proved to display similar TK activity, which activated a variety of intracellular signaling pathways, leading to alterations in the proliferative, adhesive and survival properties of CML cells. In subsequent studies, the transfer of Bcr-Abl into mouse stem cells, followed by transplantation into mice, caused a CML-like syndrome; mice transgenic for Bcr-Abl developed acute leukemia. By 1990, these findings provided convincing evidence that Bcr-Abl was produced by a leukemic oncogene. A specific inhibitor of the Bcr-Abl protein was therefore predicted to be an effective therapeutic agent for CML.

Investigators screened chemical libraries to find a drug that would inhibit that protein. An initial lead compound (of the 2-phenylaminopyrimidine class) was identified by random, high-throughput screening; that is, the in vitro testing of large compound libraries. This lead compound was then tested and modified by the introduction of methyl and benzamide groups to give it enhanced binding properties, ultimately resulting in Gleevec.

Gleevec was subsequently tested in a number of preclinical models: in vitro, in vivo (mouse models), and human ex-vivo (peripheral blood or bone marrow from patients with CML). These experiments demonstrated that Gleevec specifically inhibits the proliferation of cell lines containing Bcr-Abl, and selects for the growth of benign hematopoietic progenitors in colony-forming assays using progenitor cells from CML patients. Studies in mice also showed that Gleevec had in vivo activity against Bcr-Abl-expressing cells and that continuous exposure to Gleevec was necessary to eradicate the tumors, suggesting that this would be important for optimal antileukemic effects. Prior to clinical testing, pharmacokinetic studies in mice, rats and dogs were conducted. Gleevec demonstrated favorable oral bioavailability, and lack of significant toxicity in animal models. Gleevec also demonstrated high selectivity for Abl TKs—leaving unaffected the dozens of other tyrosine kinases that are essential for normal function.

In 1998, the Phase I clinical trials of Gleevec were launched. Once doses of 300 mg or greater were reached, 53 out of 54 patients (98 percent) achieved a complete hematologic response (white blood cell, platelet, and red blood cell counts have returned to a normal range). At that dose level, cytogenetic responses (reduction in the number of cells in the bone marrow that have the Ph chromosome) were seen in 53 percent of patients, with 13 percent achieving a complete cytogenetic response. An attractive feature of CML for clinical concept validation is that the disease can be easily monitored through analysis of blood count, and the presence of the Ph chromosome can be used as a surrogate of disease activity. In this regard, the cytogenetic responses suggested that Bcr-Abl–expressing cells either had a selective growth disadvantage or they underwent cell death in the presence of Gleevec. These results have confirmed the role of Bcr-Abl and the importance of tyrosine kinase activity in the pathogenesis of CML.

##### How Thoroughly Characterized Was the Pathway?

In many respects, the disease pathway and the mechanism of drug action were thoroughly understood and described. However, several features of CML may make the success of a single agent such as Gleevec unique for this cancer. The Bcr-Abl tyrosine kinase, present in 95 percent of patients, is sufficient to cause the disease, and in early disease, it may represent the sole molecular abnormality. Few other malignant diseases can be ascribed to a single molecular defect in a protein kinase. In that regard it was an ideal target.

Even with this rather thorough understanding, there were and are still some unknowns. For example, at the time of Gleevec’s development, no clear explanation for its impressive specificity for Abl-TK could be made. However, a series of recent biochemical and structural studies have elucidated the mechanisms responsible for the inhibition of the Bcr-Abl TK by Gleevec. TKs generally adopt similar active conformations, but can differ significantly in their inactive conformations; Gleevec inhibits Bcr-Abl specifically by binding to an inactive kinase domain conformation that is characteristic of Abl.

Gleevec displays excellent efficacy and minimal side effects with CML patients, and now represents the frontline therapy for CML. However, patients in advanced stages of the disease develop resistance to Gleevec treatment due to the acquisition of mutations in the Abl kinase domain that render the protein insensitive to this inhibitor. Second-generation drugs such as nilotinib and dasatinib have been developed that are able to target most, but not all, Gleevec-resistant mutations. Third-generation therapeutic agents are in development or clinical evaluation.

Finally, recent studies have revealed a potential “dark side” of Gleevec (Wang, 2006). Gleevec inhibits the normal cellular Abl, a downstream effector of the Eph receptors in breast cancer cells. These studies suggest that Eph-dependent tumor suppression requires Abl and is blocked by Gleevec, potentiating breast cancer promotion. Gleevec may not be overtly oncogenic, but its potential to promote some forms of tumor progression highlights the complexity of interactions between biological mechanisms that makes prediction of clinical effects from biological mechanisms difficult.

#### Application of Conceptual Framework to Gleevec

- Condition: Philadelphia chromosome positive Chronic myelogenous leukemia
- Intervention: Imatinib
- Primary Target Effect: Inhibition of abnormal tyrosine kinase activity
- Clinical Effect: Disease remission and cure

#### Strength of Evidence for Gleevec’s Primary Target Effect in Nonhuman Models

Part of the background knowledge on leukemia was that it was a cellular, not systemic disease, i.e., if the abnormally proliferating cancer cells and their progenitors could be suppressed or eliminated, the disease would be controlled or cured. Imatinib emerged from the rational drug discovery process as the lead compound for preclinical development on the basis of its selectivity against CML cells in vitro and its drug-like attributes, including pharmacokinetic and formulation properties. Imatinib was the first drug in its class of targeted tyrosine kinase inhibitors.

#### Strength of Evidence for Gleevec’s Clinical Effect in Nonhuman Models

Dose-dependent inhibition of tumor growth was seen in animals injected with human Bcr-Abl cells and treated daily with imatinib. Using a once-per-day schedule of up to 50 mg/kg, tumor growth was inhibited, but not eradicated (Druker, 1996). The reason for this modest in vivo activity became apparent from the pharmacokinetic profile of imatinib. This profiling revealed a short drug half-life in mice, which was not seen in other species (rat, dog, human). In nude mice a single dose of imatinib inhibited Bcr-Abl kinase activity for only 2 to 5 hours. A three times-per-day dosing schedule led to a continual block of Bcr-Abl kinase activity, resulting in eradication of tumors in 87 percent of imatinib-treated mice (le Coutre, 1999). On the basis of these data, it was considered likely that continuous exposure to imatinib would be required for optimal anti-leukemic effects.

#### Predictive Power of Nonhuman Model for an Effect in Humans

Several biological model systems demonstrated that Bcr-Abl is an oncogene that promotes CML pathogenesis. These model systems were important tools for elucidating the molecular mechanisms of CML formation, and to identify potential therapeutic targets. These included cultured cell models which demonstrated that the expression of Bcr-Abl could transform certain mouse cell lines and primary bone marrow cells (Ren, 2002). Animal models of in vivo CML pathogenesis demonstrated that the expression of Bcr-Abl in mouse bone marrow cells by retroviral transduction and bone marrow transplantation methods induced a myeloproliferative disorder that closely resembled CML (Daley, 1990; Kelliher, 1990; Elefanty, 1990). These models of CML proved that the Bcr-Abl kinase was sufficient to cause the disease, establishing it as the fundamental drug target.

#### Strength of Evidence for Target Effect in Humans

In a critical set of preclinical experiments conducted by Druker (Druker, 1996), imatinib was shown to suppress the proliferation of Bcr-Abl–expressing cells in vitro and in vivo. In colony-forming assays of peripheral blood or bone marrow from patients with CML, imatinib caused a 92 to 98 percent decrease in the number of Bcr-Abl colonies formed, with minimal inhibition of normal colony formation.

The standard dose-escalation, phase I study of imatinib involved escalation from 25 to 1000 mg in 14 cohorts of patients (Druker, 2001). Imatinib was rapidly absorbed after oral administration, and a mean maximal concentration was reached at steady state by once-daily administration of 400 mg. The half-life of the drug in the circulation ranged from 13 to 16 hours, and the levels of the drug increased by a factor of 2 or 3 at steady state with once-daily dosing. Blood samples from participants were tested to determine whether Bcr-Abl kinase activity was inhibited. The chosen measure was the mobility of CKRL, a major substrate of the Bcr-Abl enzyme. CRKL that is phosphorylated by BCR-ABL migrates more slowly on electrophoresis than the unphosphorylated form. Low doses (25 to 50 mg) of imatinib caused no alteration in the mobility of CRKL. An increase in the levels of the rapidly migrating unphosphorylated form and a concomitant decrease in the levels of the slowly migrating phosphorylated form were seen in patients receiving the 85-mg dose of imatinib; these changes were more prominent in patients receiving a daily dose of 140 mg and appeared to reach a plateau in patients receiving a daily dose of 250 to 750 mg.

#### Strength of Evidence for the Clinical Impact of the Target Effect in Human Disease States

In Phase I clinical trials, doses of 300 mg or greater of imatinib achieved a complete hematologic response (white blood cell, platelet, and red blood cell counts returned to a normal range) in 53 out of 54 patients (98 percent; Druker, 2001). Phase II trials were similarly successful (95 percent of patients achieved a complete hematologic response, 60 percent a major cytogenetic response, 13 percent relapse at median followup of 29 months), providing the basis for FDA approval (Kantarjian, 2002). In a 5-year followup study, 98 percent of patients showed a complete hematologic response, and the estimated overall survival rate for patients was 89 percent, with a relapse rate of about 17 percent (Druker, 2006).

#### How Well Does Conceptual Framework Capture Gleevec?

Imatinib is an ideal case to which to apply the framework. Unlike most other cancers, which are caused by a multitude of complex interacting genetic and environmental factors and therefore have many targets, CML is caused by a single aberrant protein related to a consistent chromosomal translocation. As such, researchers were able to focus all of their efforts on this single target. Nonetheless, the imatinib story is an excellent example of how evidence concerning biological mechanisms can lead to effective life-saving interventions. On balance, our conceptual framework does a good job in capturing the dimensions that contribute to the preclinical evidence in both predicting the successful clinical effects of Gleevec.

### Case Study 2 Estrogen in Post-Menopausal Women

- Intervention: Hormone Replacement Therapy (HRT)
- Primary Target Effect: Lipoprotein Metabolism
  ○ Secondary Target Effects: Blood pressure, coagulation, and carbohydrate metabolism
- Clinical Effect: [Reduction in the risk of] Coronary Heart Disease (CHD)

#### Introduction

In the 1950s, evidence began to emerge that estrogen replacement therapy among postmenopausal women lowered the risk of coronary heart disease (CHD). Lipoprotein metabolism was considered the primary target effect of estrogen, and epidemiological, clinical, and laboratory studies supported this hypothesis. Still, there remained concerns about the validity of the observational data and the incomplete picture of the relevant biological mechanism(s). In the 1980s, the evidential picture became more complex with the addition of progestin to the estrogen regime in order to reduce the [increased] risk of endometrial cancer that was seen among estrogen users. As part of the Women’s Health Initiative, which began in the 1990s, a randomized controlled trial (RCT) examined the effect of HRT on the risk of CHD.

#### Strength of Evidence for the Intervention’s Primary Target Effect in Nonhuman Models

Much of the research on animal models investigating the relationship between estrogen, lipoprotein metabolism, and CHD took place in the 1950s and relied on rudimentary measures, such as total cholesterol. Estrogen was shown to reduce the total cholesterol:phospholipids (C/P) ratio in rats and cholesterol-fed male chicks, but not rabbits (Pick, Stamler, Rodhard, et al., 1952a, 1952b; Stamler, Pick, and Katz, 1956).

#### Strength of Evidence for Clinical Effect of Target Effect in Nonhuman Models

Consistent with the findings from research on estrogen’s effect on lipoprotein metabolism, estrogen was shown to inhibit coronary atherogenesis and reverse previously induced coronary lesions among cholesterol-fed male chicks (Pick, Stamler, Rodhard, et al. 1952a; 1952b). Similarly, estrogens also resulted in lower levels of atherogenesis in rats but not rabbits (Stamler, Pick, and Katz, 1956).

Later research showed that estrogens reduced arterial lesions in female rabbits without significantly influencing plasma cholesterol levels, perhaps through direct interaction with the arterial wall or effects on plasma components other than lipoproteins (Hough and Zilversmit 1986). Although estrogen reduced the risk of atherosclerosis in sheep and cynomolgus monkeys, it did not impact lipoprotein levels, indicating that estrogen might operate through other mechanistic pathways to reduce the risk of CHD (Karas 2002).

#### Predictive Power of Nonhuman Model for an Effect in Humans

The use of gendered animal models also produced results consistent with early findings from clinical and epidemiological research. Egg-laying hens (modeling premenopausal women) had lower levels of atherogenesis and more favorable C/P ratios than male roosters, whereas ovariacteomized hens (modeling postmenopausal women) had levels of atherogenesis and C/P ratios that were similar to male roosters (Stamler, Pick, and Katz, 1956). However, for most mammalian models, estrogen appeared to exert any cardioprotective benefit through pathways other than its effect on the lipoprotein metabolism (Hough and Zilversmit 1986; Sarrel 1989).

The main issue with the use of animal models was the need to induce the disease state (i.e., hypercholesterolemia), usually through cholesterol feeding, in order to study the effects of estrogen on lipoproteins and CHD. In herbivores, such as rabbits, [total] cholesterol levels induced after cholesterol feeding were so high as to lead some to dismiss the model as irrelevant to the human disease state (Steinberg 2004). Other species, such as dogs or rats, were efficient at converting cholesterol and did not develop arterial lesions; this led some to argue against lipoproteins as a causative factor in CHD (Steinberg 2004).

Moreover, by the time progestins were added to estrogen replacement therapy, the importance of animal models in research on the relationship between HRT and CHD had declined. Evidence from animal models was weak and inconclusive regarding the effect of progestin on the risk of CHD via lipoprotein profiles.

#### Strength of Evidence for Target Effect in Humans (HRT, Lipid Protein Profile)

Clinical research produced conflicting results. In the 1970s, research had shown that while postmenopausal women had increased plasma levels of all lipoprotein patterns compared to premenopausal women, this pattern was similar to that of healthy men (Shoemaker, Forney, and MacDonald, 1977). Estrogen replacement did not result in a conversion to a premenopausal lipid profile. Rather, estrogen treatment was associated with a rise in HDL levels (potentially beneficial), a rise in VLDL levels (potentially harmful), and variable changes in LDL levels (Furman, 1971; Shoemaker, Forney, and MacDonald, 1977). Further research soon suggested that estrogen did in fact decrease LDL levels (Bush and Barrett-Connor, 1985).

However, research indicated that estrogen’s effect on lipids and lipid protein metabolism accounted for less than half of its purported cardioprotective effect (U.S. Food and Drug Administration, 1990; Espeland, et al., 1995). Other potential pathways included blood pressure, coagulation, and carbohydrate metabolism.

Progestins were shown to raise LDL levels and lower HDL levels, both of which could potentially increase the risk of CHD (Bush and Barrett-Connor, 1985; Bush, 1986; Watkins, 2007).

#### Strength of Evidence for the Clinical Impact of the Target Effect in Human Disease States

By the 1980s, the “lipid hypothesis”, namely the hypothesis that lipoprotein metabolism was a causative factor in the risk of CHD, was largely accepted by the scientific community. The results from the Lipid Research Clinics’ Primary Prevention Trial showed that reducing blood cholesterol with a pharmaceutical agent (cholestyramine) reduced the risk of CHD primary events (Steinberg, 2006). In 1984, an NIH consensus conference recommended that in order to reduce the risk of CHD, reducing blood cholesterol should be adopted as a national public health goal (Steinberg, 2006).

#### How Well Does the Framework Capture This Case Study?

The HRT-CHD case highlights important strengths and weaknesses of the conceptual framework. The case for the HRT-CHD hypothesis was constructed based on observational studies and research on surrogate endpoints, but there was insufficient evidence to determine whether HRT reduced the risk of CHD. The conceptual framework helps to systematically identify gaps in proposed mechanistic pathways and the types of evidence, mechanistic or otherwise, that should be generated to determine the effects of HRT on the risk of CHD. Indeed, if more attention had been given to the conflicting or inconclusive evidence concerning the effect of HRT on CHD via lipoprotein metabolism, the strong enthusiasm for the use of HRT to reduce the risk of CHD may have been tempered; as epidemiological and clinical evidence on surrogate endpoints mounted, less attention was given to understanding the basic mechanisms. On the other hand, the evidence suggested that HRT influenced the risk of CHD through multiple pathways (lipoprotein metabolism, blood pressure, and coagulation), and the conceptual framework does not provide guidance on how to integrate evaluations of the evidence across multiple mechanisms.