# References

1 Alonso de Lecinana M, Diez-Tejedor E, Carceller F, et al. Cerebral ischemia: from animal studies to clinical practice. Should the methods be reviewed?. Cerebrovasc Dis. Suppl 1. 2001;11:20-30. [pmid: 11244197].
2 Altar CA. The Biomarkers Consortium: on the critical path of drug discovery. Clin Pharmacol Ther. Feb. 2008;83:361-4. [pmid: 18183037].
3 Altar CA, Amakye D, Bounos D, et al. A prototypical process for creating evidentiary standards for biomarkers and diagnostics. Clin Pharmacol Ther. Feb. 2008;83:368-71. [pmid: 18091762].
4 Alvarez RH, Kantarjian H, Cortes JE. The biology of chronic myelogenous leukemia: implications for imatinib therapy. Semin Hematol. Jan. 2007;44(1 Suppl 1):S4-14. Review. [pmid: 17292736].
5 Alymani NA, Smith MD, Williams DJ, et al. Predictive biomarkers for personalised anti-cancer drug use: Discovery to clinical implementation. Eur J Cancer. Mar. 2010;46(5):869-79. [pmid: 20138504].
6 Atkins D, Best D, Briss PA, et al. Grading quality of evidence and strength of recommendations. BMJ. Jun. 19. 2004;328:1490. [pmid: 15205295].
7 Ayhan Y, Sawa A, Ross CA, et al. Animal models of gene-environment interactions in schizophrenia. Behav Brain Res. Dec. 7. 2009;204:274-81. [pmid: 19379776].
8 Benatar M. Lost in translation: treatment trials in the SOD1 mouse and in human ALS. Neurobiol Dis. Apr. 2007;26:1-13. [pmid: 17300945].
9 Bolton C. The translation of drug efficacy from in vivo models to human disease with special reference to experimental autoimmune encephalomyelitis and multiple sclerosis. Inflammopharmacology. Oct. 2007;15:183-7. [pmid: 17943249].
10 Bracken MB. Why animal studies are often poor predictors of human reactions to exposure. J R Soc Med. Mar. 2009;102:120-2. [pmid: 19297654].
11 Bush TL. The adverse effects of hormonal therapy. Cardiol Clin. Feb. 1986;4(1):145-52. [pmid: 3518931].
12 Bush TL, Barrett-Connor E. Noncontraceptive estrogen use and cardiovascular disease. Epidemiologic Reviews Epidemiol Rev. 1985;7:89-104. Review.
13 Buyse M, Sargent DJ, Grothey A, et al. Biomarkers and surrogate end points—the challenge of statistical validation. Nat Rev Clin Oncol. Jun. 2010;7(6):309-17. [pmid: 20368727].
14 Contopoulos-Ioannidis DG, Ntzani E, Ioannidis JP. Translation of highly promising basic science research into clinical applications. Am J Med. Apr. 15. 2003;114:477-84. [pmid: 12731504].
15 Crossley NA, Sena E, Goehler J, et al. Empirical evidence of bias in the design of experimental stroke studies: a metaepidemiologic approach. Stroke. Mar. 2008;39:929-34. [pmid: 18239164].
16 Daley GQ, Van Etten RA, Baltimore D. 1990. Induction of chronic myelogenous leukemia in mice by the P210bcr/abl gene of the Philadelphia chromosome. Science. Feb. 16. 1990;247(4944):824-30. [pmid: 2406902].
17 Daubert JP, Zareba W, Cannom DS, et al. Inappropriate implantable cardioverter-defibrillator shocks in MADIT II: frequency, mechanisms, predictors, and survival impact. J Am Coll Cardiol. Apr. 8. 2008;51:1357-65. [pmid: 18387436].
18 DiBernardo AB, Cudkowicz ME. Translating preclinical insights into effective human trials in ALS. Biochim Biophys Acta. Nov–Dec. 2006;1762:1139-49. [pmid: 16713196].
19 Druker BJ, Guilhot F, O’Brien SG, et al. Five-year follow-up of patients receiving imatinib for chronic myeloid leukemia. N Engl J Med. Dec. 7. 2006;355(23):2408-17. [pmid: 17151364].
20 Druker BJ, Talpaz M, Resta DJ, et al. Efficacy and safety of a specific inhibitor of the BCR-ABL tyrosine kinase in chronic myeloid leukemia. N Engl J Med. Apr. 5. 2001;344(14):1031-7. [pmid: 11287972].
21 Druker BJ, Tamura S, Buchdunger E, et al. Effects of a selective inhibitor of the ABL tyrosine kinase on the growth of BCR-ABL positive cells. Nat Med. May. 1996;2(5):561-6. [pmid: 8616716].
22 Elefanty AG, Hariharan IK, Cory S. bcr–abl, the hallmark of chronic myeloid leukaemia in man, induces multiple haemopoietic neoplasms in mice. EMBO J. Apr. 1990;9(4):1069-78. [pmid: 1691092].
23 Espeland MA, Bush TL, Mebane-Sims I, et al. 1995. Rationale, design, and conduct of the PEPI trial. Control Clin Trials. Aug. 1995;16(4 Suppl):3S-19S. [pmid: 7587218].
24 Fleming TR, DeMets DL. Surrogate end points in clinical trials: are we being misled?. Ann Intern Med. Oct. 1. 1996;125:605-13. [pmid: 8815760].
25 Furman RH. Coronary heart disease and the menopause. Ryan KJ, Gibson DC, editors. Menopause and Aging. Washington, DC. U.S. Government Printing Office. 1971:39-55.
26 Good IJ. Probability and the Weighing of Evidence. New York. Charles Griffin & Co. 1950.
27 Goodman SN. Towards evidence-based medical statistics, II: The Bayes Factor. Ann Intern Med. 1999;130:1005-13. [pmid: 10383350].
28 Harris RP, Helfand M, Woolf SH, et al. Current methods of the US Preventive Services Task Force: a review of the process. Am J Prev Med. 2001;20:21-35. [pmid: 11306229].
29 Hill AB. The environment and disease: association or causation?. Proc Roy Soc Med. 1965;58:295-300. [pmid: 14283879].
30 Hough JL, Zilversmit DB. Effect of 17 beta estradiol on aortic cholesterol content and metabolism in cholesterol-fed rabbits. Arteriosclerosis. Jan–Feb. 1986;6(1):57-63. [pmid: 3942559].
31 Kantarjian H, Sawyers C, Hochhaus A, et al. Hematologic and cytogenetic responses to imatinib mesylate in chronic myelogenous leukemia. N Engl J Med. Feb. 28. 2002;346(9):645-52. [pmid: 11870241].
32 Karas RH. Animal models of the cardiovascular effects of exogenous hormones. Am J Cardiol. Jul. 3. 2002;90(1A):22F-25F.
33 Kass RE, Raftery AE. Bayes Factors. JASA. 1995;90:773-95.
34 Kelliher MA, McLaughlin J, Witte ON, et al. Induction of a chronic myelogenous leukemia-like syndrome in mice with v-abl and BCR/ABL. Proc Natl Acad Sci U S A. Sep. 1990;87(17):6649-53. [pmid: 2204061].
35 Kluft C. Principles of use of surrogate markers and endpoints. Maturitas. Apr. 15. 2004;47:293-8. [pmid: 15063482].
36 Kola I, Landis J. Can the pharmaceutical industry reduce attrition rates?. Nat Rev Drug Discov. Aug. 2004;3:711-5. [pmid: 15286737].
37 le Coutre P, Mologni L, Cleris L, et al. In vivo eradication of human BCR/ABL-positive leukemia cells with an ABL kinase inhibitor. J Natl Cancer Inst. 1999;20;91:163-8.
38 Macleod MR, Ebrahim S, Roberts I. Surveying the literature from animal experiments: systematic review and meta-analysis are important contributions. BMJ. Jul. 9. 2005;331:110. [pmid: 16002897].
39 Nowell PC. Discovery of the Philadelphia chromosome: a personal perspective. J Clin Invest. Aug. 2007;117:2033-5. [pmid: 17671636].
40 Oldenhuis CN, Oosting SF, Gietema JA, et al. Prognostic versus predictive value of biomarkers in oncology. Eur J Cancer. May. 2008;44:946-53. [pmid: 18396036].
41 Pick R, Stamler J, Rodhard S, et al. Estrogen-induced regression of atherosclerosis in cholesterol-fed chicks. Circulation. Dec. 1952;6(6):858-61. [pmid: 12998110].
42 Pick R, Stamler J, Rodhard S, et al. The inhibition of coronary atherosclerosis by estrogen in cholesterol-fed chicks. Circulation. Aug. 1952;6(2):276-80. [pmid: 14936224].
43 Prentice RL. Surrogate endpoints in clinical trials: definition and operational criteria. Stat Med. Apr. 1989;8:431-40. [pmid: 2727467].
44 Ransohoff DF. How to improve reliability and efficiency of research about molecular markers: roles of phases, guidelines, and study design. J Clin Epidemiol. Dec. 2007;60:1205-19. [pmid: 17998073].
45 Ransohoff DF. Promises and limitations of biomarkers. Recent Results Cancer Res. 2009;181:55-9. [pmid: 19213557].
46 Ren R. The molecular mechanism of chronic myelogenous leukemia and its therapeutic implications: studies in a murine model. Oncogene. 2002;21:8629-42. [pmid: 12476309].
47 Royall R. Statistical Evidence: A Likelihood Paradigm. London. Chapman and Hall. 1997.
48 Shoemaker ES, Forney JP, MacDonald PC. Estrogen treatment of postmenopausal women: benefits and risks. JAMA. 1977;238(14):1524-30. [pmid: 578221].
49 Stamler J, Pick R, Katz LN. Experiences in assessing estrogen antiatherogenesis in the chick, rabbit, and man. Ann N Y Acad Sci. 1956:596-619. [pmid: 13373231].
50 Steinberg D. Thematic review series: the pathogenesis of atherosclerosis. An interpretive history of the cholesterol controversy, part V: the discovery of the statins and the end of the controversy. J Lipid Res. Jul. 2006;47(7):1339-51. [pmid: 16585781].
51 Steinberg D. Thematic review series: the pathogenesis of atherosclerosis. An interpretive history of the cholesterol controversy: part I. J Lipid Res. Sep. 2004;45(9):1583-93. Epub 2004 Apr 21. [pmid: 15102877].
52 Suppes P. A Probabilistic Theory of Causality. Amsterdam. Amsterdam. 1970.
53 Susser M. Judgment and causal inference in epidemiologic studies. Am J Epidemiol. 1977;105:1-15. [pmid: 318797].
54 't Hart BA, Amor S, Jonker M. Evaluating the validity of animal models for research into therapies for immune-based disorders. Drug Discov Today. Jun. 15. 2004;9:517-24. [pmid: 15183159].
55 Taube SE, Clark GM, Dancey JE, et al. A perspective on challenges and issues in biomarker development and drug and biomarker codevelopment. J Natl Cancer Inst. Nov. 4. 2009;101:1453-63. [pmid: 19855077].
56 U.S. Food and Drug Administration. Fertility and Maternal Health Drugs Advisory Committee. Washington, DC. Federal Drug Administration. 1990. Meeting Minutes, 14 June 1990.
57 Vandenbroucke JP. When are observational studies as credible as randomised trials?. Lancet. May. 22. 2004;363:1728-31. [pmid: 15158638].
58 Wagner JA. Overview of biomarkers and surrogate endpoints in drug development. Dis Markers. 2002;18:41-6. [pmid: 12364809].
59 Wang JY. Eph tumor suppression: the dark side of Gleevec. Aug. 2006;8(8):785-6.
Watkins ES. The Estrogen Elixir. Baltimore, MD. The Johns Hopkins University Press. 2007.