# Objective

Our objective was to identify and pilot test a framework for the evaluation of evidence from knowledge of biological mechanism.