# Limitations and Future Research

While we believe the framework provided to be the starting point for any discussions of the value of mechanistic knowledge, much remains to be done in the form of both further refinement and implementation. In terms of refinement, while the framework components themselves represent a minimally sufficient set of dimensions, the optimal set of component questions within each of these dimensions requires further work. The more specificity that is provided in the sub questions, the more operational the framework becomes, but also potentially the more limited.

More work must also be done on how best to quantitate or weigh the impact both within and between various dimensions. Because many of the inferences cannot fall back on randomization, the same kinds of evidential judgments used when assessing observational studies must be applied to many of these designs. Building such a quantitative network or chain of inferences is akin to building complex risk models, and the relevance of such techniques to this application should be explored. As shown in some of the examples provided, it is possible to roughly quantitate the evidential value of the entire drug development process; refining this for specific interventions or in nondrug applications, will require substantially more work, yet is clearly achievable.

Most of the ideas presented herein are already part of the conversation of translational medicine and device and drug development. However, putting these together in the form of an evidential framework and a statistically sound definition of evidence is conceptually new territory for most working on either side of the translational divide. Developing a clear expert consensus, as there has been for traditional hierarchies of evidence, will require substantially more work. In addition, producing more clarity in how different forms of evidence interact will require further interdisciplinary research in both foundations and application. Bodies of work that can be mined for such development include that of expert elicitation and multiple bias modeling.

The pilot examples of the use of the framework demonstrated both its potential strength and areas for further work. It was clear in both cases the framework could be applied qualitatively, and that such application could illuminate those domains in which the evidence made the relationship between the therapy and the outcome more or less likely. In both cases, we saw that a limited number of pathways, a well characterized pathophysiology, and a clearly delineated target within those pathways were key elements. However, how the various qualitative observations can be quantitatively assessed and the relative weights of various dimensions or algorithmic combination thereof, requires further work.

It is important to note that judgments and decisions similar to those required of this framework are made every day in the assessment of newly evolving technologies. Whether a drug should proceed to clinical testing, whether a particular patient subgroup is more or less likely to respond to a drug, or whether weak direct evidence is sufficient in the face of strong mechanistic evidence to make therapeutic decisions, and finally, whether RCT evidence applies to a particular individual are judgments made on the basis of linkages and generalizations that have their grounding in mechanistic reasoning. Medicine has long known that mechanistic reasoning has its limitations in predicting the behavior of complex systems, but on the other hand, it has also shown that few therapies could have been developed or applied to individuals without such reasoning. It is not possible for medicine to reject such reasoning as a formal source of medical evidence, challenging as it is to formally assess and quantitate such information. We see the framework provided herein is the beginning of that process.