# Executive Summary

## Background

Virtually all current frameworks for the evaluation of the strength of evidence for an intervention’s effect focus on the quality of the design linking the intervention to a given outcome. Knowledge of biological mechanism plays no formal role, in spite of the fact that such knowledge is typically the basis for the development of the intervention. At best, mechanistic knowledge comes in indirectly, through the choice of endpoints, target populations, and perhaps under the vague rubric of “biological plausibility.” But nowhere in any of the evidence grading schemas, new statistical methodologies or other technology assessment guidelines do we have a formal language and structure for how knowledge of how an intervention works should enter the process.

## Objective

Our objective was to identify and pilot test a framework for the evaluation of the evidential weight of mechanistic knowledge in evidence-based medicine and technology assessment.

## Methods

We used multiple resources and perspectives to help us develop a framework the evaluation of the evidential weight of mechanistic knowledge. We carried out the following six steps:

Step 1 Focused literature review
Step 2 Development of draft framework
Step 3 Workshop with technical experts
Step 4 Refinement of framework
Step 5 Development of two case studies
Step 6 Pilot test of framework on case studies

## Results

### Step 1 Focused Literature Review

We conducted comprehensive literature reviews in two broad areas: evaluation of surrogate endpoints and the value and use of animal models in translational research. Both searches encompassed the publication dates between 2000 and 2009, with additional references found before and after those dates through reference and citation searches. Reviews were conducted on 125 articles on animal models, 133 on surrogate markers, and 24 on evidential grading systems. An annotated bibliography summarized 93 of the articles on animal models as well as 103 of the articles on certain points. All of these articles were mapped into a preliminary version of a conceptual framework.

### Step 2 Development of Draft Framework

Based on preliminary review of related literature, an initial draft framework was devised and used as the basis for mapping the annotated bibliographies, as well as discussion in a subsequent workshop. This initial framework was substantively modified on the basis of the work conducted for this report and is presented below:

Strength of evidence for:

1. Existence of pathway.
2. Existence of pathway in humans.
3. Completeness of pathway.
4. Alternate, competing, or compensatory pathways
5. Similarity to other interventions/mechanisms with known clinical effects
6. Adverse event mechanisms

### Step 3 Invited Workshop With Technical Experts

An exploratory workshop was held with experts in translational medicine, toxicology, philosophy evidence-based medicine and a variety of other fields. A draft conceptual framework was presented and discussed, and each participant presented their own experience and knowledge concerning the use of mechanistic knowledge in either interpreting or developing research on emerging therapies. The workshop was summarized and the conceptual framework revised.

### Step 4 Development of Framework

Based our review of the literature described above as well as the technical input gathered in the workshop on the draft framework, we propose the following final version of the framework for evaluation of mechanistic evidence:

Strength of evidence for the:

1. Intervention’s target effect in nonhuman models.
2. Clinical impact of target effect in nonhuman models.
3. Predictive power of nonhuman model for an effect in humans
  3t The predictive power of the target effect model
  3c The predictive power of the clinical effect model
4. Intervention’s target effect in human disease states.
5. Clinical impact of the target effect in human disease states.

This is the minimally sufficient series of steps necessary for such a framework, and this has sufficient generality to apply to virtually all types of interventions. This framework is demonstrated graphically in Figure A below:

Figure A Schematic of mechanistic framework model

This figure diagrams the relationship between components of mechanistic information in nonhuman models and the same in humans. Arrows, labeled “1” and “4” depict the relationship between Intervention and Target biological effect in nonhuman and human models respectively. An arrow labeled “3t” marks the predictive power of the relationship in nonhuman models for predicting the same relationship in human models. Arrows labeled “2” and “5” depict the subsequent relationship between Target Biological effect and Clinical effect in nonhuman and human models respectively. An arrow labeled “3c” marks the predictive power of the relationship in nonhuman models for predicting the relationship in human models.

The propagation of the strength of evidence is through a Bayesian algorithm, with the strength of evidence represented by the degree to which the probability of a clinical effect is modified by evidence from the component steps. This modeling makes clear how strong mechanistic evidence can be necessary for proper inferences, yet still, by itself, yield very low probabilities of success for a given intervention.

### Step 5 Pilot Test of Framework in two Case Studies

As part of a companion project, two in depth case studies were developed to see how the conceptual framework being developed would apply to actual examples. The two case studies were of Gleevec for the treatment of chronic myelogenous leukemia and estrogen use in menopausal women for the prevention of heart disease. These case studies were summarized and mapped into the conceptual framework.

## Discussion

We utilized multiple resources and perspectives including literature review and consultation with experts at our institution to develop a framework for the use of mechanistic knowledge in the evaluation of the effectiveness of medical interventions. This framework has several features combining work from a variety of fields that represent an important step forward in the rigorous assessment of such evidence.

1. It uses a definition of evidence based on inferential effect, not study design.
2. It separates evidence based on mechanistic knowledge from that based on direct evidence linking the intervention to a given clinical outcome.
3. It represents the minimum sufficient set of steps for building an indirect chain of mechanistic evidence.
4. It is adaptable and generalizable to all forms of interventions and health outcomes.
5. It mirrors in the evidential framework the conceptual framework for translational medicine, thus linking the fields of basic science, evidence-based medicine and comparative effectiveness research.

## Limitations and Future Research

While we believe the framework provided to be the starting point for any discussions of the value of mechanistic knowledge, much remains to be done in the form of both further refinement and implementation. In terms of refinement, while the framework components themselves represent a minimally sufficient set of dimensions, the optimal set of component questions within each of these dimensions requires further work. The more specificity that is provided in the sub questions, the more operational the framework becomes, but also potentially the more limited.

More work must also be done on how best to quantitate or weigh the impact both within and between various dimensions. Because many of the inferences cannot fall back on randomization, the same kinds of evidential judgments used when assessing observational studies must be applied to many of these designs. Building such a quantitative network or chain of inferences are similar to complex quantitative risk models, and the relevance of such techniques to this application should be explored. As shown in some of the examples provided, it is possible to roughly quantitate the evidential value of the entire drug development process; refining this for specific interventions or in nondrug applications, will require substantially more work, yet is clearly achievable.

The pilot examples of the use of the framework demonstrated both its potential strength and areas for further work. It was clear in both cases that the framework could be applied, and that such application could illuminate those domains in which the evidence made the relationship between the therapy and the outcome more or less likely. In both cases, we saw that a limited number of pathways, a well characterized pathophysiology, accurate measures and a clearly delineated target within those pathways were key elements. However, how the various qualitative observations can be quantitatively assessed and the relative weights of various dimensions, or algorithmic combination thereof, requires further work.

## Conclusions

The formal language and logic of evidential assessment in evidence-based medicine and comparative effectiveness research has no formal place for incorporating knowledge of “how things work” in medicine. This project has provided a conceptual framework for that assessment, with proposals for how this might be combined with direct evidence to provide a way of capturing all the ways of knowing in medicine, defined both on the group level and at the level of the individual.

Much work remains to be done in terms of refining the subcomponents of these dimensions and in their quantification or combination. Further developing this framework can help not only in the accurate representation of evidence for therapeutic decisionmaking and medical policy, but can potentially speed the development of medical interventions by demonstrating how and where mechanistic evidence can augment direct evidence. A potentially even more important outcome is that this framework can help bring together those communities working on the development and the assessment of therapies, who rarely seem to communicate except occasionally at the translational divide, and whose different views of what constitutes legitimate evidence has been a source of both misunderstanding and indeed conflict between those communities of researchers. Developing a common framework for evidence may be a first step towards true interdisciplinary, translational knowledge