# Acknowledgments

- Karen Robinson, M.Sc., Ph.D.
  Johns Hopkins University
- Harry Marks^*^, Ph.D.
  * Deceased, 2010
  Johns Hopkins University