# Discussion

We utilized multiple resources and perspectives including literature review and consultation with experts at our institution to develop a framework for the use of mechanistic knowledge in the evaluation of the effectiveness of medical interventions. This framework has several features combining work from a variety of fields that represent an important step forward in the rigorous assessment of such evidence.

- It uses a definition of evidence based on inferential effect, not study design.
- It separates evidence based on mechanistic knowledge from that based on direct evidence linking the intervention to a given clinical outcome.
- It represents the minimum sufficient set of steps for building an indirect chain of mechanistic evidence.
- It is completely adaptable and generalizable to all forms of interventions and health outcomes.
- It mirrors in the evidential framework the conceptual framework for translational medicine, thus linking the fields of basic science, evidence-based medicine and comparative effectiveness research.