# Conclusions

The formal language and logic of evidential assessment in evidence-based medicine and comparative effectiveness research has no formal place for incorporating knowledge of “how things work” in medicine. This project is provided a conceptual framework for that assessment, with proposals for how this might be combined with impure: direct evidence to provide a way of capturing all the ways of knowing in medicine, defined both on the group level and at the level of the individual. Much work remains to be done in terms of refining the subcomponents of these dimensions and in their categorization. Developing such a framework can help not only in the accurate representation of evidence for therapeutic decision-making and medical policy, but can potentially speed the development of medical interventions by demonstrating how and where mechanistic evidence can augment direct evidence. A potentially even more important outcome is that this framework can help bring together those communities working on the development and the assessment of therapies, who rarely seem to communicate except occasionally at the translational divide, and whose different views of what constitutes legitimate evidence has been a source of both misunderstanding and indeed conflict between those communities of researchers. Developing a common framework for evidence may be a first step towards true interdisciplinary, translational knowledge.