# Background

Interest has increased in recent years in “comparative effectiveness,” that is, assessing the efficacy of new or established medical interventions, with particular emphasis on head to head comparisons of established therapies, or understanding their real-world performance. Randomized controlled trials (RCTs), while the ostensible gold standard for establishing efficacy and sometimes effectiveness, have well recognized liabilities, most notably the time and expense it often takes to mount them, as well as the sometimes limited scope of the questions they address.

Alternatives to RCTs include a variety of observational designs. Those attracting considerable attention are typically derived from very large databases, often assembled for non-research purposes, such as hospital billing, reimbursement, prescription data, electronic patient records, etc. Studies derived from such data sources promise real-world relevance, and relatively rapid results, compared to some RCTs. The middle ground is occupied by observational designs with original data gathering and RCTs that utilize surrogate endpoints—for example, death versus tumor progression, elevated LDL or coronary artery narrowing versus MI or death.

A dilemma facing patients, physicians, regulatory entities, insurance providers, guideline developers and others with an interest in evidence assessment involves: (1) how pertinent existing RCT evidence is to the decisions they have to make and (2) how informative and reliable results from either observational designs or RCTs that use surrogate outcomes are in determining either efficacy or effectiveness. It is generally recognized that observational designs are subject to subtle biases that can have large effects (e.g., WHI), and that data not gathered for research purposes often lacks the precision or validity to make reliable inferences. The main approaches to these problems currently being discussed are three-fold; improving the quality and completeness of the underlying data, using innovative statistical methodologies to diminish the effects of confounding, and the development of evidence grading schemes to distinguish reliable from unreliable evidence. The ultimate goal of such efforts is to derive conclusions through these approaches that are nearly as reliable and perhaps more relevant for policy purposes than RCTs.

What is notably absent from these conversations is the role that should be played by knowledge of mechanism, and how this can help in the evaluation of observational evidence, including the detection of effect modification (e.g., “personalized medicine”). With the ascendance of the evidence-based medicine, there is no formal role for mechanistic knowledge in the evidence-evaluation framework. At best, mechanistic knowledge comes in indirectly, through the choice of endpoints, target populations, and perhaps under the vague rubric of “biological plausibility.” But nowhere in any of the evidence grading schemas, new statistical methodologies or other technology assessment guidelines do we have a formal language and structure for how knowledge of how an intervention works should enter the process. The closest we have is in the prior probability distribution functions of Bayesian approaches, but this begs the question of how to reliably determine how much mechanistic knowledge is worth.

## Defining "Evidence"

Evidence-based medicine defines the strength of evidence in terms of how the information was produced, e.g., RCT, case-control study, case series, etc. (Harris et al., 2001; Atkins et al., 2004) The definition to be employed here is based instead on its inferential effect, following principles of Bayesian inference and probabilistic causality (Suppes, 1970). We define evidence as information that modifies the probability that an intervention will have a non-null causal effect on an outcome. The strength of evidence is related to the magnitude of change in that probability, with the most familiar Bayesian metric being the Bayes factor or its logarithm. (Good, 1950; Kass and Raftery, 1995; Royall, 1997; Goodman, 1999). It is expressed in a simple version of Bayes theorem as follows:

### Bayes Theorem

Prior odds of clinical effect × Bayes Factor = Posterior odds of a clinical effect

Bayes factor ( H_A_ v s . H_0_ ) = (Probability of observed data under H_A_)/(Probability of observed data under H_0_)

Where:

H_0_ = Null hypothesis that intervention has no clinical effect

H_A_ = Alternative hypothesis that intervention has a clinical effect

In the case of diagnostic tests, the Bayes factor is equivalent to the likelihood ratio commonly used in EBM (Good, 1950; Kass and Raftery, 1995; Royall, 1997). As in the case of diagnostic testing, it is critical to separate the posterior probability of a hypothesis (aka, the predictive value of a given result) from the strength of evidence. A diagnostic test can be extremely powerful, yet if the prevalence of the tested disease (a.k.a. prior probability of disease) is low enough, the positive predictive value of that test can still be quite low. Similarly, mechanistic evidence for an intervention’s effect can be very powerful without making the probability of that effectiveness high. For the probability of effectiveness to be high, evidence from clinical research is usually required; how much is in part determined by the strength of the mechanistic evidence. As was noted in a description of the role of mechanistic evidence in the IARC determinations of carcinogenicity, “There is an implicit trade-off between the strength of the evidence in humans and the strength of the mechanistic data needed: the weaker the evidence in humans, the stronger the mechanistic data must be to warrant a classification [as a human carcinogen].”

Under the theory of probabilistic causality, a cause is defined as condition whose presence or absence, all other factors being equal, changes the probability of an outcome. (Suppes, 1970) Thus, all interventions with non-zero clinical effects, independent of other factors, are by definition causes of the outcome. This links the evidential criteria used in EBM and proposed herein to causal criteria proposed in epidemiology and clinical medicine (Hill, 1965; Susser, 1977). We will therefore use the language and framework of causation interchangeably with that of therapeutic effectiveness.

#### The Strength of Evidence Provided by the Preclinical Development Process

The Bayes factor can be used to roughly quantify the strength of evidence provided by pre-clinical drug development. Many in the pharmaceutical industry lament the poor yield of pre-clinical drug testing, but this low yield is a reflection of the posterior probability of success, not the evidential value of the research. Based on data from pharmaceutical companies from 1991–2000, Kola (Kola and Landis, 2004) reported that roughly 10 percent of drugs entering Phase I studies were ultimately approved for use, with about half of failures due to nonclinical reasons (e.g., market considerations). It has been estimated that roughly 1000 compounds are screened for every one that enters clinical testing. Thus, the ratio of screened compounds to approved therapies is about 10,000:1, for a yield of about 1/10,000 if we picked a compound at random to test clinically. While the success rate of the pre-clinical process seems low (10 percent), it has increased 1000 times over the success rate to be expected by choosing compounds at random. So the pre-clinical process is hugely informative, raising the odds of success about 1000-fold, with that multiplier being the value of the Bayes factor.

In contrast, if we presume that the clinical development process must raise the probability of clinical efficacy from 10 percent to 95 percent, that requires a Bayes factor of only about (95/5)÷ (10/90) = 171, and about half that level if nonclinical failures are omitted. This informal calculation shows that while pre-clinical evidence may provide an insufficient basis to upon which choose human therapies, it still provides quantitatively more evidence than the clinical phase of testing, which in this example provided only 43 percent of the total (=log 171/(log 1000 + log 171)). Thus, mechanistic information has substantial evidential value, and its strength affects the amount of evidence required from the clinical testing process. It is critical to note how different that perspective is from that of EBM, which relegates such preclinical work to the realm of “nonevidence”. The usage here is consistent with that of Vandenbroucke, who notes that the predictive power of stronger designs may be due more to the prior probability needed before such a design is implemented than the evidential strength of the design itself. (Vandenbroucke, 2004)

In another study, Contopoulos et al. (Contopoulos-Ioannidis et al., 2003) looked at 25,190 basic science studies published around 1980 and found 101 in which there were claims of potential clinical utility. Of these, 19 resulted in at least one positive clinical trial, and 5 were ultimately licensed for clinical use. Using the latter number as a count of the number of successful technologies, we see numbers not qualitatively dissimilar from those reported for drug development; approximately 250 basic science studies per technology that entered clinical development (25190/101), with 1 in 20 of these (5/101) ultimately succeeding. Again, the basic research process has increased the odds of success more than does the clinical research process, this time by a factor of about 12 (250/20). So while the translational and developmental process is often decried for its small yield of usable therapies, it must be recognized that it increases the odds of success by several orders of magnitude, leaving the clinical evaluation process to increase it yet further to justify clinical use.