# Workshop Proceedings Biological Mechanisms in Evidence-Based Medicine

Johns Hopkins Evidence-Based Practice Center

PI: Steven N. Goodman

Summary of Workshop Proceedings: Monday, November 30, 2009, 8:30 a.m to 4:00 p.m., Johns Hopkins Bloomberg School of Public Health

The goal of this one-day workshop was to bring together an interdisciplinary, international group of translational scientists, philosophers, toxicologists, historians of science, epidemiologists and evidence-based medicine researchers to explore the translation of biological mechanistic knowledge to effects of interventions in humans.

In attendance

[underlined: Participants]: Lindley Darden, Ph.D., University of Maryland (by phone); David Eddy, M.D., Ph.D., Archimedes, Inc.; Charles Flexner, M.D., John Hopkins School of Medicine; John Groopman, Ph.D., Johns Hopkins Bloomberg School of Public Health; Jeremy Howick, M.Sc., Ph.D., Oxford University/London School of Economics; David Kass, M.D., John Hopkins School of Medicine; Peter Keating, Ph.D., Université du Québec à Montréal (by phone); Gary Kelloff, M.D., National Cancer Institute; Scott Kern, Ph.D., John Hopkins School of Medicine; Malcolm Macleod, M.D., Ph.D., University of Edinburgh

[underlined: Project Investigators]: Steven Goodman, M.D., M.H.S., Ph.D., Johns Hopkins Bloomberg School of Public Health; Harry Marks, Ph.D., Johns Hopkins University; Karen Robinson, Ph.D., John Hopkins School of Medicine; Jason Gerson, Ph.D., Johns Hopkins Bloomberg School of Public Health; Emily Evans, M.P.H., Johns Hopkins Bloomberg School of Public Health.

[underlined: Invited Guests]: Steve Fox, M.D., S.M., M.P.H., AHRQ Project Officer; Gary Persinger, National Pharmaceutical Council.

## I Roadmap and workshop goals

### Presenter: Steve Goodman

Following welcome and introductions, Dr. Goodman discussed workshop agenda and goals. Workshop being held early in project timeline, meant to be “creative brainstorming” session that informs development of conceptual framework. Key points:

- Presented conceptual map for the project: football field representing scale of probability of therapeutic efficacy. End zones represented by “Preclinical research,” and “Proof.” “Preclinical/mechanistic research,” Early developmental research,” and “clinical trials” represent 1–10 percent, 11–30 percent, 31–90 percent of the field, respectively, of probabilistic advances toward proof. Key idea: even if preclinical/mechanistic research affords “only” a 10 percent probability of an intervention working, still provides significant evidential value, and is preferable to simply picking therapies, devices or molecules at random.
- Reviewed U.S. Preventive Services Task Force criteria and analytic framework, with particular attention to how the task force defines “linkages” and “fit” between various steps in a mechanistic process.
- Presented domains of Biological Mechanisms in Evidence-Based Medicine (BMEBM ) framework, including: (1) strength of evidence for existence of a pathway, (2) strength of evidence for the existence of a pathway in humans, and (3) completeness of pathway from intervention to clinical endpoint.
- Raised key questions for the group to consider over the course of the workshop:
  ○ Does framework capture relevant dimensions of “mechanism” to assess the strength of supporting evidence? What is missing?
  ○ Should framework focus on causal pathways? Is there a better conceptualization? Would different terminology be preferable?
  ○ How operational is framework, or any framework that tries to capture gaps in knowledge? To what extent can lack of knowledge be known in real time?
  ○ How should dimensions be rated/coded?
  ○ How reproducible are judgments likely to be?
  ○ How should dimensions be combined?

## II Invited Presentations

The Project Investigators invited subset of participants to give a brief presentation. Presentations intended to highlight their research and address ways in which research confronts questions related to biological mechanisms and preclinical evidence.

### A Summarizing the evidence from animal models of neurological disease: publication bias, poor internal validity, and (perhaps) some efficacy

#### Presenter: Malcolm Macleod

Dr. Macleod presented research concerning systematic reviews of animal models of interventions in stroke. Described search strategy/methods; presented findings from one review. Key points:

- Described how internal validity and external validity was assessed in systematic review.
- Suggested that reported efficacy (32 percent) of animal studies in stroke is reduced by publication bias (8 percent), randomization bias (6 percent), and comorbidity bias (14 percent), effectively reducing efficacy to 4 percent.
- Presented way of graphically summarizing evidence from animal studies. Graphical display indicates whether hypotheses have been confirmed or refuted, size of particular experiment, overall number of experiments in that field, and assessment of quality of evidence. Goal would be to use display to illustrate strength of evidence for each causal link hypothesized in a mechanism.

##### In discussion

[underlined: Eddy, Kass and Howick]: clarification re: probability of finding efficacious intervention in humans, given that animal study was of “high quality,” according to Macleod’s definitions.

[underlined: Macleod]: In 15 to 20 interventions his group has reviewed, only tPA demonstrated efficacy in humans. Virtually all animal experiments demonstrate an effect in animals, so that cannot be a barometer of the quality of animal studies.

[underlined: Groopman]: Difficulties of getting accurate pathology diagnosis in mice and how that contributes to measurement error.

[underlined: Macleod]: Scoring animal neurobehavior is difficult; there are challenges in measuring murine stroke effects; suggested ways to mitigate those errors.

### B Biological Mechanisms: A Perspective from Philosophy of Science

#### Presenter: Lindley Darden

Dr. Darden provided overview of key definitions and features of MDC (Machamer, Darden, Craver) account of biological mechanisms. Key points:

- Researchers interested in understanding biological mechanisms need to specify mechanisms in terms of entities and activities, start and set up conditions, finish and termination conditions, productive continuity, organization, degree of regularity (deterministic or probabilistic), character of the phenomena, spatial features, temporal features, and contextual features (e.g., integration of levels).
- MDC view distinguishes between mechanism schema (signaling more complete understanding; glass boxes) and mechanism sketches (signaling incompleteness; black and grey boxes). Dimensions of schemas include completeness, detail (abstract/specific), evidentiary support (how-possibly, how-plausibly, how-actually), and scope (generality).
- Reasoning strategies in examining mechanisms: construction, evaluation, and revision. Focused on evaluation, which seeks to remove incompleteness. Described moves from how- possibly/plausibly/actually: accumulation of experimental evidentiary support.
- Need to consider what kind of mechanism is being examined: (a) normal biological mechanism, (b) mechanism in disease, or (c) mechanism of intervening in the disease.

### C Use of biological mechanisms in the Archimedes model

#### Presenter: David Eddy

Dr. Eddy addressed the question: How can we use information on intermediate outcomes (e.g., mechanisms, biomarkers, surrogates) to draw conclusions about effects of treatments on health outcomes? He described the Archimedes model (AM). Key points:

- AM is built up from physiological pathways (at “clinical” or organ level, not cellular/molecular/genetic level), and organized around four submodels: individuals and population models, physiology models, health care delivery system model, and outcomes. Tests and treatments incorporated into an AM meant to reproduce disease mechanisms and diagnostic/health care processes. Presented model of coronary artery disease and MI occurrence to illustrate features and complexity of AM.
- Primary challenge for AM similar to BMEBM—determining whether mechanism is accurate predictor of health outcome. For AM, goal is to understand the relationship between intermediate variables and health outcomes. But many unknown variables—re: pathophysiological pathways and effects of intervention—can produce effects that:
  (1) are the reverse of what is expected, (2) in the expected direction but of the wrong magnitude, or (3) are as expected within some range but unexpected outside that range. Both AM and BMEBM trying to understand extent to which biomarkers, surrogate endpoints, or mechanisms produce unexpected effects.
- BMEBM should develop metrics to quantitatively measure gaps in knowledge of mechanisms: help predict “surprises” re: magnitude and direction of effects. Suggested doing survey of randomly chosen clinical trials of new treatments and count proportion in which effect on biomarkers as expected, but effect on health outcomes unexpected (i.e., by current medical theory or mathematical models that try to account for mechanisms).

##### In discussion

[underlined: Goodman]: BMEBM will review surrogate outcomes literature—empirical attempt to represent the “probability of surprise,” since surrogates are, in a sense, mechanistic outcomes.

[underlined: Macleod and Kern]: Archimedes should be cautious re: how it incorporates findings from the clinical trial literature into models, since many types of bias and poor study quality could result in misleading conclusions.

[underlined: Kass]: Do “black boxes” that link variables represent statistical correlations?

[underlined: Eddy]: While an AM tries to capture all known causal relationships in particular disease or pathway, always something in the pathway about which we don’t know.

[underlined: Kass]: Given the sheer complexity of models, has AM simulation ever reached very counter-intuitive conclusions?

[underlined: Eddy]: Overall (qualitatively) this has not been the case; quantitatively, however, they have observed, at the level of specific variables, surprises in direction and magnitude.

### D Translating Basic Science to Prevention in High Risk Populations

#### Presenter: John Groopman

Dr. Groopman’s presentation addressed topic of risk/hazard assessment in carcinogenesis, with particular focus on formaldehyde and human cancers. Spoke of how International Agency for Research on Cancer (IARC) considers evidence from animal experiments in making determinations about what agents are carcinogenic to humans. Key points:

- Epidemiology driving evidence-gathering about risks in humans is decreasing, as occupational sites of potentially high exposure (e.g., manufacturing plants) have moved to developing world. More research in developed world focusing experimental model mechanistic data.
- If compound that has limited epidemiological data found to act through a “relevant mechanism,” (e.g., resulting in DNA damage), can be elevated from IARC Group 2A to Group 1.
  ○ [underlined: Goodman]: Is such a change in classification “merely” the function of arguments or a function of strong empirical evidence?
  ○ [underlined: Groopman]: Large number of compounds for which there will never be enough statistical power to do an epidemiological investigation. Absent epidemiological evidence, IARC will rely on experimental data emerging from mechanistic studies that assess DNA damage following exposure.
- Summarized IARC assessment of formaldehyde exposure risks. While overall assessment that formaldehyde belonged in Group 1 not contentious, much debate among IARC members about whether formaldehyde—a well-established cause of nasopharyngeal cancer—could also be labeled as cause of myeloid leukemia. Presented findings from recent epidemiological study of embalmers, formaldehyde exposure and cancer risk.
  ○ [underlined: Goodman]: Study might be a good example of a subgroup analysis that teases out emerging evidence about a hypothesized biological mechanism, one that may be based on prior mechanistic knowledge.
  ○ [underlined: Marks]: Formaldehyde may be a “reverse finding” story, in which the epidemiological finding subsequently generates research on the mechanism.

### E Reflections on the pathobiology of cardiac resynchronization therapy

#### Presenter: David Kass

Dr. Kass’s talk described lessons learned from development of cardiac resynchronization therapy (CRT). Described CRT and its effects on the heart, as well as measures used to assess whether CRT results in improvements in pump function and stroke volume. Key points:

- CRT was first cardiology intervention approved without mortality data. FDA approval of CRT was based on MIRACLE trial of 600 patients (relatively small sample), and not based on mortality, both anomalous in cardiology. CRT also approved before studies demonstrating who would clinically benefit were conducted. Basic research regarding mechanism was done post-approval; only now learning what mechanisms might be.
  ○ [underlined: Goodman]: Reason that CRT trial was so small and accepted surrogate endpoints rather than mortality was due to fact that CRT grounded in straightforward physiological model that we believe in and is fairly deterministic.
- Findings from clinical trials aimed at explaining why about 35 percent of patients with dyssynchrony who receive CRT—who seem like good candidates for the device—do not benefit from it. Largest study—PROSPECT trial—found that, for about half the patients, CRT offered no benefit (or whose dyssynchrony was worsened); in other half, patients who experienced perfect resynchronization still had highly variable surrogate endpoint improvements, suggesting no correlation between extent of resynchronization and long-term outcomes.
- Key messages from PROSPECT: (1) we either have inadequate measures of synchrony, or (2) reverse remodeling involves more than resynchronization (i.e., the proposed mechanism was wrong). As a result, Kass and colleagues have gone “back to the bench.” Through these experiments they’ve learned much about potential molecular mechanisms that may be involved in heart failure.

##### In discussion

[underlined: Flexner]: Heart replacement was never subjected to a prospective randomized trial, but widely accepted as an effective therapy for heart failure. Why is evidence for these biomechanical procedures accepted with few qualifications, when more complex procedures seem to have a higher evidence threshold?

[underlined: Kass]: Perhaps it’s because heart replacement was based on a simple hemo-dynamic mechanism.

[underlined: Kern and Goodman]: There have been other seemingly simple mechanisms and procedures that we got wrong.

[underlined: Kern]: Part of what happens in development of mechanical interventions is that researchers take a narrow view of the problem; not concerned with off-target effects and assume there are no covariates about which to be concerned. When we test drugs we are always concerned with such things.

[underlined: Kass:] We’ve historically oversimplified heart failure story, and therapies we’ve developed either do not work, or, when they do seem to work (e.g., beta blockers and ACE inhibitors), we don’t fully understand how they do.

## III Case study: Cancer targeted therapies: Gleevec

### Discussant: Scott Kern

In order to ground discussion in a particular example, Project Investigators decided to include a case study concerning the development of the drug Gleevec to treat chronic myeloid leukemia (CML). Given his expertise in bench research broadly, and familiarity with development of Gleevec in particular, Investigators invited Dr. Kern to lead the discussion. Highlights of case study discussion:

- Kern discussed some of his work in developing a measure of pharmacogenetic synergy, a quantitative approach to capturing interactions between two agents or an agent and a disease. Discussed key concept in this work—pharmacogenetic window—which measures magnitude of the advantage achieved by a genetic classification of a subject.
- [underlined: Kern]: In some respects we were lucky with Gleevec because CML tumors have single, genetically simple tumor that the drug targeted. Key message of Kern’s comments: in early stage drug development we ought to be using quantitative measures or a numerical threshold based on sound math to make decisions. He cautioned against relying on “stories”—namely scientists’ discretion and qualitative judgments—in making determinations about potential of an agent.
- [underlined: Marks]: Tension between our incomplete understanding of causes of disease condition heterogeneity in humans on one hand and early drug development experiments (in vitro, animal models), which are intentionally designed to reduce or suppress heterogeneity, on the other. [underlined: Kern]: We should only accept evidence from simple, early developmental models as generalizable after we have introduced many other variables and see that our variable of interest still explains vast majority of overall variation.

## IV Reviewing the initial draft of the BMEBM conceptual framework

Dr. Goodman led discussion of domains contained in the initial draft of BMEBM conceptual framework. Highlights of discussion:

- Re: “strength of evidence for existence of intervention’s pathway” domain. As presently conceived, this domain includes quality (design and execution) and strength (quantitative effect) of experimental evidence in preclinical models, as well as number and variety of experimental models. [underlined: Goodman]: We are trying to capture something about “robustness and the ability to predict,” a domain that captures the extent to which preclinical studies have tried to reflect biological complexities.
  ○ [underlined: Macleod]: Transgenic models—now frequently used in pathway work that feeds into drug development—are part of an effort to better reflect this biological complexity.
  ○ [underlined: Kelloff:] Transgenic models, though by no means perfect, are better than in vitro cancer cell lines and leukemia transplant models used in the past. Knock-in experiments presently conducted in adult transgenic animals put in a specific gene thought to be involved in a pathway. Disadvantage of these experiments is that they are narrowed to one gene; advantage is that they match up the drugs that are molecularly targeted, and are able to test efficacy in an in vivo system.
- Re: “strength of evidence that the pathway exists in human disease states” domain.
  [underlined: Kern:] Closely consider what is meant by “strength of evidence.” Key question is: “Does a pathway variable that you are trying to change with a drug remain a dominant variable as you move closer to the natural heterogeneity of patients?”
- There was some discussion about the language contained in the framework. Does domain 1a refer to something like “internal validity?” Does domain 1b mean something like “generalizability or “repeatability?” Does domain 1c mean something like “robustness” or “repeatability across different models?”
- [underlined: Kass]: Framework should somehow capture the reality that the vast majority of the animal models that we currently use are not very predictive of human disease. With 90 percent of all basic research is done in small rodents, there is a significant translatability problem of animal models. Absence of genetic heterogeneity in animal models is further exacerbated by “co-pharmacotherapy” issue: no animal studies attempt to mimic human experience of exposure to other therapies meant to treat a particular disease.
- [underlined: Eddy, Macleod, Goodman and Marks]: Spoke about how an empirical component for BMEBM could be designed, in particular talking through issues of how a score/scale might be developed and challenges of data collection.
- [underlined: Goodman]: While these challenges are real, we must start from first principles, which is how the other hierarchies (e.g., GRADE) were built. One must begin by developing a common vocabulary for “what’s going to matter.” At present, we do not have any way to talk about these things.

The workshop adjourned.