# Annotated Bibliography of Surrogate Endpoints Literature, With Framework Mapping

This component of the project was conducted before the framework described in this document was fully developed and finalized. A preliminary framework was used into which the various articles were mapped. This mapping was done in the form of bolded codes that appear at the end of each article description, and correspond to the following dimensions.

1. Strength of evidence for existence of intervention’s pathway
  a. Quality (design and execution) and strength (quantitative effect) of experimental evidence in preclinical models.
  b. Number of experimental models
  c. Variety of experimental models (e.g. animal species)
2. Strength of evidence that the pathway exists in human disease states.
  a. Strength of evidence for animal/in vitro model’s relevance for human disease state.
  b. Ex vivo evidence
  c. Evidence that pathway occurs in complete physiologic system (e.g. functioning hearts vs. heart tissue.)
  d. Evidence from human physiologic experiments.
3. Completeness of proposed mechanistic pathway. (From intervention to clinical endpoint)
  a. Gaps in pathway (including whether intervention/exposure can exert effect on target due to issues of bioavailability, metabolism, delivery, etc.)
  b. Remoteness of the mechanistic outcomes from clinical outcomes.
  c. Strength of evidence linking proximal (i.e. surrogate) to distal (i.e. definitive) clinical endpoints
4. Evidence for alternate, competing or compensatory pathways that can:
  a. Produce outcome through pathways independent of intervention’s effect
  b. Produce non-therapeutic outcomes through pathways dependent on intervention
  c. Interfere with intervention’s pathways
5. Strength of evidence that mechanism is similar to other interventions with known clinical effects
6. Adverse event mechanisms

## I Annotated articles

1. Altar CA, Bounos D, Amakye D, et al. A prototypical process for creating evidentiary standards for biomarkers and diagnostics. Clin Pharmacol Ther. Feb. 2008;83(2):368-71. [pmid: 18091762].

2. Altar CA. The Biomarkers Consortium: on the critical path of drug discovery. Clin Pharmacol Ther. Feb. 2008;83(2):361-4. [pmid: 18183037].

The above two articles present a framework for assessing evidence for biomarker qualification, a task viewed as important to the FDA’s Critical Path initiative. Table 1 of the Altar et al. paper includes a “Prototype ‘evidence map,’” which contains categorical description of different types of scientific evidence potentially relevant to biomarker qualification. It outlines a system of assigned letter grades to subcategories of evidence. “Theory on biologic plausibility” is weighted the least important of the seven subcategories, followed by “Interaction with pharmacologic target,” and “Pharmacologic mechanistic response.” This might serve as a useful model for BMEBM instrument development. [1a, 3c]

3. Alymani NA, Smith MD, Williams DJ, et al. Predictive biomarkers for personalised anti-cancer drug use: Discovery to clinical implementation. Eur J Cancer. Mar. 2010;46(5):869-79. [pmid: 20138504].

This article examines failure to translate initially promising cancer (especially solid tumor) predictive biomarkers into clinically useful applications and highlights the need to develop a robust clinical biomarker development methodology: discovery, validation, qualification and implementation; see Figure 1. Most useful to BMEBM is discussion of discovery and qualification. Due to molecular complexity and heterogeneity, there is a dearth of evidence at discovery phase (re: causal mechanistic relationship between a particular molecular pathway and the clinical outcome in individual patients). Frequently, correlative relationships between biomarkers and clinical endpoints are relied upon to identify leads, especially using ‘omic’ platforms. Qualification (defined as “the evidentiary process of establishing a causal or correlative relationship between the biomarker and the clinical end-point or other biological or pathological end-point”) relies in part on appeals to expert opinion (panels convened by the FDA). [1a, 3a, 3c]

4. Antoine DJ, Mercer AE, Williams DP, et al. Mechanism-based bioanalysis and biomarkers for hepatic chemical stress. Xenobiotica. 2009;39:565-77. [pmid: 19621999].

This review article summarizes the potential of novel mechanism-based biomarkers of hepatic stress, which provide information concerning the molecular basis of drug-induced liver injury (DILI). The authors emphasize the importance of our ability to link the chemistry of the drug to a clinically observed adverse drug reaction by an understanding of the intracellular and extracellular signaling pathways involved (that is, the mechanisms of action). They discuss a number of examples/models of DILI biomarkers, endorsing the view that an integrated analysis of the biochemical, molecular, and cellular events provides an understanding of biological factors which ultimately determine the balance between xenobiotic detoxification and liver injury. [1b, 3a, 6]

5. Bhattacharya S, Mariani TJ. Array of hope: expression profiling identifies disease biomarkers and mechanism. Biochem Soc Trans. 2009;37:855-62. [pmid: 19614607].

This article examines the utility of genome-wide microarray technologies in the identification of biomarkers and disease mechanisms. The authors—reviewing recent advances in the area of respiratory diseases — classify microarray-based discovery into three components: biomarker detection, disease (sub)classification and identification of causal mechanism. They describe initial limitations/deficiencies in using microarray, including: experimental design/study size, analytical methods and probe sequences. As many of these limitations are better understood or have been overcome, they strike a hopeful tone that microarray, when used in combination with animal models and genetic studies, particularly focusing on quantitative variable analysis, can provide unexpected power to identify disease mechanisms. [2b, 3c]

6. Bhogal N, Balls M. Translation of new technologies: from basic research to drug discovery and development. Curr Drug Discov Technol. 2008;5:250-62. [pmid: 18690893].

This article describes new omics’ technologies, high-throughput analyses and imaging techniques that have potentially enormous value to the drug development process. These are leading to a gradual shift away from the traditional animal testing-dominated paradigm, to one based on using human cells and tissues alongside human microdosing to develop new therapeutic agents. The authors argue that a human-focused approach holds the key to reducing the attrition rates in drug development, particularly with regard to the development of treatments for human diseases with complex and varied etiologies that cannot readily be simulated using animal models or which are to be targeted by highly human-specific agents. Tables 1 and 2, and Figures 2 and 3 are particularly useful for BMEBM purposes. [2b, 3c]

7. Biomarker Definitions Working Group. Biomarkers and surrogate endpoints: preferred definitions and conceptual framework. Clin Pharmacol Ther. Mar. 2001;69(3):89-95. [pmid: 11240971].

This commentary by an expert group convened by the National Institutes of Health provides definitions of the terms biomarker, clinical endpoint and surrogate endpoint in order to help build consensus in describing biological measurements used in therapeutic development and assessment. Most useful for BMEBM is the conceptual model of the relationship of biomarkers, surrogate endpoints, and the process of evaluating therapeutic interventions, which includes a box labeled “Evidence that a biomarker is reasonably likely to predict clinical benefit or risk (Figure 1). Also includes very brief discussion of biomarker validation as reflecting causal or mechanistic associations of the intervention with the disease process (as opposed to a statistical approach). [3b, 3c, 5]

8. Boffetta P. Biomarkers in cancer epidemiology: an integrative approach. Carcinogenesis. 2010;31:121-6. [pmid: 19959558].

This article identifies various reasons for the increased use of biomarkers in cancer epidemiology, including: (1) the fact that the identification of new carcinogens, characterized by complex exposure circumstances and weak effects, has become increasingly difficult with traditional epidemiological approaches; (2) the increasing understanding of mechanisms of carcinogenesis and (3) technical developments in molecular biology and genetics. The author distinguishes between biomarkers of exposure, effect (biological events that take place in the continuum between exposure and cancer development), and susceptibility (identification of high-risk subgroups of the population), arguing that molecular epidemiology should strive to address several components of the carcinogenic process in a single conceptual model. While this article does not focus on biomarkers in the context of therapeutic interventions, the discussion of effect biomarkers—particularly how they may be used to increase the specificity and the sensitivity in the definition of the outcome—is relevant to BMEBM. [2a, 3a, 3c]

9. Carden CP, Banerji U, Kaye SB, et al. From darkness to light with biomarkers in early clinical trials of cancer drugs. Clin Pharmacol Ther. 2009;85:131-3. [pmid: 19151637].

This opinion piece suggests that the traditional clinical trial infrastructure is inefficient, slow and costly, and serves the cancer research community particularly poorly. The authors recommend more widespread use of adaptive early biomarker-driven clinical trials testing molecularly targeted agents that are able to not only question but also answer key scientific and clinical hypotheses. Such trials can arguably have a major impact on understanding of disease biology, decreasing the risk of late and costly drug attrition. These trials of targeted agents require definitive evidence of target modulation in tumor cells by the agent under evaluation, in carefully selected patients. [3a]

10. Carroll KJ. Biomarkers in drug development: friend or foe? A personal reflection gained working within oncology. Pharm Stat. 2007;6:253-60. [pmid: 17351904].

In this personal reflection piece, the author sounds a cautionary note concerning the use of biomarkers in drug development. Where biomarkers are used for candidate drug screening for intrinsic activity or proof of mechanism, there seems little impediment to their use and the burden falls squarely on the sponsor to be sure the biomarker endpoint helps to make the right decisions. However, using biomarkers as surrogate endpoints for clinical outcome to support drug approval is more troublesome. Establishing a new biomarker as a true surrogate endpoint using published statistical criteria is extremely demanding, if not impossible. The author argues that a lower burden of evidence is required and, consequently, that greater risks be taken, in order to use new biomarkers as substitutes for clinical outcome. [3b, 3c]

11. Chau CH, Rixe O, McLeod H, et al. Validation of analytic methods for biomarkers used in drug development. Clin Cancer Res. 2008;14:5967-76. [pmid: 18829475].

This paper focuses on the general principles of biomarker validation in the drug development process, with an emphasis on assay validation. Table 1 describes the potential uses of biomarkers in each phase of drug development, and includes a “preclinical studies” phase (development of appropriate animal models that feature biomarker properties comparable with those seen in patient populations to enhance predictivity; role in validation of new disease models; assess toxicity and safety of drug). [2b, 3a]

12. Chetty RK, Ozer JS, Lanevschi A, et al. A systematic approach to preclinical and clinical safety biomarker qualification incorporating Bradford Hill’s principles of causality association. Clin Pharmacol Ther. Aug. 2010;88(2):260-2. [pmid: 20592723].

This article addresses questions regarding the optimal methods of collecting and evaluating scientific evidence for the clinical qualification of a biomarker, with a focus on toxicology biomarkers. The authors propose a novel application to assist and accelerate the drug development process by prioritizing biomarker candidates and evidence, an application based on Bradford Hill’s principles of causality association. The criteria related to biological plausibility and coherence are of interest for BMEBM purposes. [3a, 6]

13. Clark DP. Ex vivo biomarkers: functional tools to guide targeted drug development and therapy. Expert Rev Mol Diagn. 2009;9:787-94. [pmid: 19895224].

In this review, the authors explore the promise of ex vivo biomarkers in the development of cancer drugs. Most of the currently utilized predictive biomarkers for therapeutic decision-making provide information regarding the presence or absence of the drug target but reveal little about the functional circuitry of the signaling network that the drug must also impact. Ex vivo biomarkers are dynamic molecular markers evoked from living tumor cells after removal from the patient. Live tumor cells are procured from a patient and are exposed to a stimulus, such as a growth factor, sometimes in the presence of a modulator like a drug, to evoke ex vivo biomarkers. These biomarkers are then assembled into a signaling profile that provides functional information about the tumor that is not available using traditional processing. The authors argue that ex vivo biomarkers provide valuable mechanistic information that may facilitate drug development and guide the clinical selection of targeted therapeutics or identify potential responder subpopulations (e.g., ex vivo biomarkers from model systems, such as murine xenografts). [2b, 3b]

14. Coate LE, John T, Tsao MS, et al. Molecular predictive and prognostic markers in non-small-cell lung cancer. Lancet Oncol. 2009;10:1001-10. [pmid: 19796752].

This paper reviews current predictive and prognostic biomarkers in non-small-cell lung cancer (NSCLC). The authors assess their potential clinical use and explore recent data pertaining to genome-wide approaches for treatment selection in NSCLC. The paper raises some interesting questions of relevance to BMEBM. For instance, even as molecular analysis advances, we still do not know whether the molecular profile of a tumor changes at the time of disease recurrence after surgery, or even after therapy for more advanced disease. There is little information as to whether primary and metastatic tumors always share the same molecular profile, although there is some evidence for molecular discordance between early and metastatic disease. If this finding is shown to be a frequent occurrence, repeat biopsy with molecular profiling of fresh tissue might be required when treatments change, especially if the new treatment has a specific molecular target. Table 3 summarizes the prognostic and predictive markers in NSCLC, and includes a “level of evidence” column. [2b, 3a]

15. Colburn WA. Biomarkers in drug discovery and development: from target identification through drug marketing. J Clin Pharmacol. 2003;43:329-41. [pmid: 12723454].

16. Colburn WA. Optimizing the use of biomarkers, surrogate endpoints, and clinical endpoints for more efficient drug development. J Clin Pharmacol. 2000;40:1419-27. [pmid: 11185662].

This is a highly useful pair of papers by an author who has thought deeply about biomarkers and biological mechanisms of disease progression and therapeutic intervention. The author argues that early in discovery and development, the biomarker should at least reflect activity that is mediated through the theoretical disease mechanism of action. Later in development, the biomarker should represent mechanism-based processes that are critical to disease progression and that are appropriately altered by effective therapeutic interventions. Some biomarkers, he points out, are simply associated with the disease, do not drive the disease process, or are not altered by therapeutic intervention that acts on the disease mechanism. False-positive results occur when there is an assumption that the biomarker is a critical part of the disease process when in fact it is only loosely associated with the disease process or a random event that has inadvertently coincided with disease diagnosis and progression. The author raises the interesting point that the lack of agreement between biomarkers and clinical endpoints—often attributed as the “fault” of the former—is often caused by the selection of an unreliable endpoint. [3a, 3b, 3c]

17. Collins CD, Purohit S, Podolsky RH, et al. The application of genomic and proteomic technologies in predictive, preventive and personalized medicine. Vascul Pharmacol. 2006;45:258-67. [pmid: 17030152].

This article reviews recent technological advances in genetics, genomics, proteomics, and bioinformatics that may help advance and accelerate biomarker discovery. The authors focus on the development of predictive biomarkers for chronic diseases such as diabetes, cancer and hypertension, suggesting that effective prevention requires sensitive and specific biomarkers that can accurately identify the at-risk population before the onset of clinical symptoms. [2b, 3b]

18. Danhof M, Alvan G, Dahl SG, et al. Mechanism-based pharmacokinetic-pharmacodynamic modeling-a new classification of biomarkers. Pharm Res. 2005;22:1432-7. [pmid: 16132354].

This article lays out the principles of mechanism-based PK/PD modeling, which the authors argue “constitutes a basis for better understanding of the biological system of interest providing a basis for extrapolation and prediction” than empirical descriptive models (presumably they mean correlative relationships). They propose a seven-level classification of biomarkers containing specific mathematical expressions for processes on the causal path between drug administration and response (described in Figure 1). Their “causal-chain” approach emphasizes construct validity (evidence that a biomarker shares a causal mechanism with an ultimate clinical endpoint), similar to Malkesman et al. (2009). [2a, 3c]

19. Danna EA, Nolan GP. Transcending the biomarker mindset: deciphering disease mechanisms at the single cell level. Curr Opin Chem Biol. 2006;10:20-7. [pmid: 16406766].

The authors of this insightful piece recognize the promise of proteomics for advancing our understanding and treatment of many diseases. They caution, however, that while ‘omic approaches can inform us about molecular signatures as markers of disease state, continued research into biological mechanism is critical. Taking examples from viral infection, autoimmunity, and cancer research, they argue that detailed analyses of disease-associated signaling networks have the potential to be more mechanistically informative than large-scale proteomic profiling approaches, providing insight into the cellular processes involved in pathogenesis, disease progression and therapeutic resistance. [2a, 2b, 3a]

20. Day M, Balci F, Wan HI, et al. Cognitive endpoints as disease biomarkers: optimizing the congruency of preclinical models to the clinic. Curr Opin Investig Drugs. 2008;9:696-706.

This article examines the role of cognitive biomarkers in neuropsychiatric and neurodegenerative disorders. By focusing on cognition as a potential disease biomarker, the authors raise important questions of how symptoms of human disease are modeled in animals, including: (1) Will the preclinical and clinical cognitive endpoints track with the initiation, progression, remission and relapse of the disease?; (2) Can the same test parameters be employed across species?; (3) Has congruency between the effects of compounds been demonstrated in the same tests in rodents, non-human primates and humans?; and (4) Can the preclinical and clinical tests differentiate extraneous confounding variables? The paper includes what the authors refer to as a “utilitarian classification” of biomarker types and a tool for assessing the strength of biomarkers (see Table 1; explored in greater detail in Day et al. 2009). [1c, 2a, 3a]

21. Day M, Rutkowski JL, Feuerstein GZ. Translational medicine—a paradigm shift in modern drug discovery and development: the role of biomarkers. Adv Exp Med Biol. 2009;655:1-12. [pmid: 20047030].

The authors of this paper present a “utilitarian classification” of biomarkers. The typology consists of 5 types of biomarkers (target validation, target/compound interaction, PD activitiy, disease biomarker and disease modification, patient stratification and adaptive design). The utility of this system is represented in Figures 2–4 of the paper, which suggest a semi-quantitative scoring system that helps assess the strength of the program overall and identification of the areas of weaknesses in each of the biomarkers needed along the biological progression path. [3a, 3b]

22. De Gruttola VG, Clax P, DeMets DL, et al. Considerations in the evaluation of surrogate endpoints in clinical trials. Summary of a National Institutes of Health workshop. Control Clin Trials. 2001;22:485-502. [pmid: 11578783].

This article focuses primarily on the development of statistical models to evaluate biomarkers and surrogate endpoints. The authors recognize the importance of using emerging mechanistic knowledge to build appropriate statistical models, arguing that new techniques are needed for testing the validity of presumed mechanisms and for updating the evaluation of biomarkers and surrogates with new mechanistic evidence and clinical data. The authors make a number of recommendations in this area, including: developing models that can accommodate measurement error and missing data/informative censoring for investigating biomarkers in different disease areas; evaluating latent variable and other models using patient-specific data for prediction; building models to incorporate longitudinal measurement of biomarkers and sequential treatments; considering a variety of estimation procedures (e.g., classical methods, empirical Bayes, or Markov Chain Monte Carlo techniques). [3c]

23. Dhani N, Siu LL. Clinical trials and biomarker development with molecularly targeted agents and radiotherapy. Cancer Metastasis Rev. 2008;27:339-49. [pmid: 18379730].

This paper examines paradigms of drug development used for cytotoxic chemotherapeutic agents (CCAs). The authors state that high throughput techniques in genomic, proteomic and metabolomic profiling should allow for more effective preclinical investigation of CCAs with the identification of biomarkers or indicators of treatment response, ultimately resulting in increased clinical efficacy and appropriate patient selection. They caution that while assessment of CCAs in validated preclinical models may be helpful to guide clinical trial design and to identify patient sub-populations most likely to benefit, results from preclinical experiments may not necessarily correlate with the clinical experience. They strike a hopeful note, suggesting that the ongoing evolution of more reproducible ‘omic profiling assays will make the early evaluation of multiple markers in human phase 0 studies a useful addition to preclinical biomarker development. [2b, 3b]

24. Dudley JT, Butte AJ. Identification of discriminating biomarkers for human disease using integrative network biology. Pac Symp Biocomput. 2009:27-38. [pmid: 19209693].

This paper presents a framework for the identification of disease-specific protein biomarkers through the integration of biofluid proteomes and inter-disease genomic relationships using a network paradigm. The authors make the case that while a more traditional biomarker discovery process might start with the disease of interest to identify biomarker candidates in a “bottom-up” approach, a “top-down” approach may be more efficient. This approach begins with the broad space of human disease and full compliments of biofluid proteomes to quickly discern candidate protein biomarkers discriminately associated with a disease condition. [2b]

25. Fine BM, Amler L. Predictive biomarkers in the development of oncology drugs: a therapeutic industry perspective. Clin Pharmacol Ther. 2009;85:535-8. [pmid: 19295504].

This brief perspective piece examines the opportunities and challenges associated with codeveloping predictive biomarkers alongside new therapeutics, using a few specific examples targeting cancer. The authors make two main points: (1) In spite of the success in the development of trastuzumab/Herceptin, incorporating predictive biomarkers into drug development for faster, smaller, cheaper, and ultimately more successful clinical development is difficult. The instances in which researchers are working with the prior knowledge (incl. preclinical mechanistic evidence) that was available in the development of trastuzumab may be rare. (2) Our understanding of predictive biomarkers for a particular drug is likely to evolve for many years after initial regulatory approval is given for the drug; in many cases, highly predictive biomarkers may not be identified and confirmed until after completion of pivotal clinical studies. [1a, 3a, 3c]

26. Fleming TR, DeMets DL. Surrogate end points in clinical trials: are we being misled?. Ann Intern Med. 1996;125:605-13. [pmid: 8815760].

This widely-cited paper begins with the observation that effects on surrogate end points often do not predict the true clinical effects of interventions. The authors examine many explanations for this failure (e.g., existence of causal pathways of the disease process that are not mediated through the surrogate end point and that might be influenced differently by the intervention). They contend that the most plausible explanation for failure is usually that the intervention has unintended mechanisms of action that are independent of the disease process. These unintended mechanisms can readily cause the effect on the true clinical outcome to be inconsistent with what would have been expected solely on the basis of evaluation of surrogate end points. [3c]

27. Fleming TR. Surrogate endpoints and FDA’s accelerated approval process. Health Aff (Millwood). 2005;24:67-78. [pmid: 15647217].

Building on Fleming and DeMets (1996), this paper considers issues related to validating surrogate endpoints (i.e., identifying when effects on biomarkers can accurately predict when treatment truly provides tangible benefit to patients). The author proposes an endpoint hierarchy describing the relative reliability of outcome measures when used to evaluate clinical benefit. He also considers the issues in the implementation of the FDA’s accelerated-approval process, where treatments only known to be biologically active can be marketed to the public while scientific trials are under way to determine whether these agents truly are more effective than toxic. Though focused on clinical as opposed to preclinical studies, the paper raises fundamental questions about evidence evaluation. The author argues that validation of a surrogate should be based on both in-depth clinical insights and empirical evidence in which one should (ideally) have a comprehensive understanding of the causal pathways of the disease process and of the intervention’s unintended and intended mechanisms of action. The paper includes a proposed 4-level endpoint hierarchy for outcome measures, and the author laments that most current surrogates occupy the lowest level, where evidence regarding biological mechanism is weakest. [2a, 3c]

28. Floyd E, McShane TM. Development and use of biomarkers in oncology drug development. Toxicol Pathol. Suppl 1. 2004;32:106-15. [pmid: 15209410].

This paper offers a useful description of the preclinical development of biomarkers in oncology research. Preclinically, biomarkers can facilitate selection of animal models and of lead compounds tested in those models. They can demonstrate pharmacological and PD mechanisms-of-action in in vitro and in vivo preclinical models. Some biomarkers such as those measuring apoptosis or signaling pathways can be used to mathematically model the effects of anticancer drug combinations to predict optimum clinical treatment regimens. Biomarker assays already established for diagnostic use and treatment monitoring in humans can be modified and evaluated preclinically to assess their validity for use in clinical trials with a particular drug candidate. The authors present a useful conceptual framework for assessing evidence of biomarker safety and efficacy (Figure 1), as well as an evidence-based 3-level hierarchy (Figure 2). Many Level-1 and Level-2 (the lower two levels) biomarkers destined for translation to the clinic are evaluated preclinically to establish that a marker is robust in a relevant model using the particular drug under development. [1a, 2a, 3a]

29. Frank R, Hargreaves R. Clinical biomarkers in drug discovery and development. Nat Rev Drug Discov. 2003;2:566-80. [pmid: 12838269].

This paper provides a good overview of biomarker terminology and validation, and provides useful examples from cardiology, neurology, oncology, psychiatry, as well as emerging imaging technologies. The authors provide a basic typology of biomarkers to guide drug development, consisting of target, mechanism and clinical biomarkers (Figure 2). They argue that the objective is to deploy these biomarkers as early as possible, first to confirm hitting the target and then to test whether hitting a target alters the pathophysiological mechanism and altering this mechanism affects clinical status. The authors also make use of the DeMets/Fleming diagrams (Fleming and Demets, 1996) re: how biomarkers can lead to erroneous conclusions (Figure 3). In addition to the four categories of errors discussed by DeMets/Fleming, they offer a fifth, more subtle, reason that a biomarker might ‘fail’, and this is by providing potentially misleading information. The authors contend that erroneous conclusions can be drawn regarding the usefulness of a biomarker when the biomarker might not correlate well with the gold-standard clinical assessor because the biomarker is more sensitive or the gold-standard assessor is irrelevant to a subset of the patient population, a novel mechanism, or a new indication. Finally, the authors suggest that the development of biomarkers for diagnostic and prognostic use in diseases with asymptomatic phases is particularly challenging and can take a long time, as their validation is by necessity often linked to long-term clinical outcomes. [3a, 3b, 3c]

30. Glassman RH, Ratain MJ. Biomarkers in early cancer drug development: limited utility. Clin Pharmacol Ther. 2009;85:134-5. [pmid: 19151638].

The authors of this short think piece offer a healthy skepticism of the utility of biomarkers in current drug development research. They suggest that the goals of early clinical trials are to: determine whether the formulation is acceptable; screen for toxicities not predicted by preclinical toxicology studies; assess relationships among dose, schedule, plasma concentrations, toxicities, and efficacy; and determine whether an expensive phase III program should be initiated. They argue that thus far, biomarker studies are neither necessary nor sufficient to meet these needs. A positive effect on a biomarker is not sufficient to conclude that a drug has antitumor activity or that a dose is optimal. Although biomarkers are potentially important tools in early clinical trials in oncology, to date they have not been shown to make cancer drug development more efficient or effective. The authors conclude that biomarker use should be limited to situations in which there is a strong scientific basis, a testable hypothesis, and a valid, precise assay method. [1a, 3a, 3b]

31. Gollob JA, Bonomi P. Historic evidence and future directions in clinical trial therapy of solid tumors. Oncology (Williston Park). 2006;20:10-8. [pmid: 16773840].

This paper provides an overview of treatments in renal cell cancer (RCC), melanoma and various solid tumors. The authors explain that the FDA has accepted significant results in clinical trials using surrogate endpoints as the basis for drug approval including the amount of tumor reduction, or tumor response (TR). They argue that although TR would seem to be a necessary precondition for improved survival, clinical studies have not consistently demonstrated a correlation between the two in patients with RCC. Moreover, TR may not be an appropriate endpoint for evaluating the effects of the new targeted therapies, whose putative mechanisms are generally cytostatic rather than cytotoxic. Clinical trials suggest that some patients with other solid tumors, such as lung cancer, may derive clinical benefit from treatment that helps stabilize their disease. The authors conclude that use of a variety of endpoints as well as different trial designs may provide an adequate basis for investigating the benefits/risks of newer therapies. [3b, 3c]

32. Goodsaid F, Frueh F. Biomarker qualification pilot process at the U.S. Food and Drug Administration. AAPS J. 2007;9:E105-8. [pmid: 17408233].

33. Goodsaid F, Papaluca M. Evolution of biomarker qualification at the health authorities. Nat Biotechnol. 2010;28:441-3. [pmid: 20458312].

34. Goodsaid FM, Frueh FW, Mattes W. Strategic paths for biomarker qualification. Toxicology. 2008;245:219-23. [pmid: 18280028].

The above three papers describe recent FDA initiatives concerning the qualification and regulatory evaluation of biomarkers. The authors draw a distinction between context-independent qualification (where proposed test methods can be qualified across multiple contexts of use) and context-dependent qualification processes. The authors suggest that while context-independence may be useful for research on toxicity biomarkers (especially for animal experiments), a context-dependent approach is required for biomarker qualification in drug development. For example, evidentiary standards for assessing preclinical and clinical data may vary according to whether a biomarker is predictive, diagnostic, or mechanistic. They describe a pilot process undertaken at the FDA consisting of a Biomarker Qualification Review Team that evaluated study protocols and reviewed study results for the qualification of novel biomarkers of drug safety, using appropriate preclinical, clinical, and statistical considerations. [1a, 2a, 3a, 3b]

35. Goulart BH, Clark JW, Pien HH, et al. Trends in the use and role of biomarkers in phase I oncology trials. Clin Cancer Res. 2007;13:6719-26. [pmid: 18006773].

This paper systematically reviewed abstracts submitted to the American Society of Clinical Oncology annual meeting (1991–2002) and the publications related to these abstracts to assess the use and role of biomarkers in phase I oncology trials. Twenty percent of American Society of Clinical Oncology phase I abstracts from 1991 to 2002 included biomarkers. This proportion increased over time (14 percent in 1991 compared with 26 percent in 2002). Independent predictors of the use of biomarkers included NCI sponsorship, submission in the time period of 1999 to 2002, adult population, and drug family (biological agents). Biomarkers supported dose selection for phase I studies in 11 of 87 of the trials (13 percent) emanating from these abstracts. Biomarker studies provided evidence supporting the proposed mechanism of action in 34 of 87 of the published trials (39 percent). The authors found that biomarkers made a minimal contribution to dose and schedule selection for phase I studies, but had greater effect in providing evidence confirming target modulation in human subjects. Their results suggest that acceptable toxicity and some evidence for antitumor effect remain the main end points used for decisions to proceed or not proceed with further drug development, and that use of biomarkers in Phase I studies is not warranted at this time. [1a, 3a]

36. Hampel H, Mitchell A, Blennow K, et al. Core biological marker candidates of Alzheimer’s disease—perspectives for diagnosis, prediction of outcome and reflection of biological activity. J Neural Transm. 2004;111:247-72. [pmid: 14991453].

This review examines three candidate cerebrospinal fluids biomarkers for Alzheimer’s disease (AD). The authors state that part of the rationale for the selection of these biomarkers was their ability to provide reasonable evidence for association with key mechanisms of pathogenesis or neurodegeneration in AD. At the time of their review, however, the preliminary and retrospective nature of the majority of findings, the absence of assay standardization, and the lack of comparison patient populations provided weak evidence for the usefulness of the biomarkers, particularly for predictive, diagnostic, or treatment evaluation purposes. [1a, 2b, 3a]

37. Hong H, Goodsaid F, Shi L, et al. Molecular biomarkers: a US FDA effort. Biomark Med. 2010;4:215-25. [pmid: 20406066].

This paper summarizes the current status of molecular biomarkers used for FDA-approved drug products, and discusses the challenges and future perspectives for the identification and qualification of molecular biomarkers. Specific FDA programs and research projects related to molecular biomarkers are also discussed for supporting regulatory review in the future. [1a, 3b]

38. Hunter DJ, Losina E, Guermazi A, et al. A pathway and approach to biomarker validation and qualification for osteoarthritis clinical trials. Curr Drug Targets. 2010;11:536-45. [pmid: 20199395].

This review outlines work done in other fields with regards biomarker validation and qualification and the lessons that may be learned by osteoarthritis (OA) researchers. The authors contend that defining a universally agreed upon path for biomarker validation and qualification is needed to address many of the challenges faced in OA drug development. These challenges include OA heterogeneity (patterns of onset and clinical presentation, different patterns of joint involvement, variations in rate of disease progression), and the current lack of a clear and reliably consistent disease modifying therapy. The paper proposes a qualification path that may be suitable for OA and presents concrete steps that might help achieve this. [1a, 2b, 3a]

39. Hurko O. The uses of biomarkers in drug development. Ann N Y Acad Sci. 2009;1180:1-10. [pmid: 19906255].

The paper, which focuses on diseases of the brain, suggests that although the value of surrogate markers is significant, such biomarkers are rare. Other, nonsurrogate biomarkers are, however, increasingly being used to reduce the risks of drug development. The author contends that any given biomarker is typically useful for only one of four types of risk reduction: (1) an inappropriate dosing regimen; (2) enrollment of nonresponsive subjects into clinical trials; (3) an inability to detect an efficacy signal quickly and reliably in chronic disorders; or (4) delayed recognition of potential side effects and/or toxicity. The author argues that a biomarker suitable for one purpose is usually not suitable for the other three. Although these considerations apply to all drug development, both the need and availability of appropriate biomarkers in each category vary between therapeutic areas. [3c, 6]

40. Jacobs A. An FDA perspective on the nonclinical use of the X-Omics technologies and the safety of new drugs. Toxicol Lett. 2009;186:32-5. [pmid: 18809476].

This paper explores the use of “omics” platforms for the evaluation of general toxicology, reproductive toxicology, the carcinogenicity potential of pharmaceuticals. The authors contend that though significant progress has been made in the standardization of procedures, challenges remain for evaluation of pharmaceuticals for regulatory purposes, because of off-target toxicologic effects, as well as issues of interpretation and the large number of biologic variables that can affect results (species/strain, genetic variations, diet, age, dose, duration, and weight of animals). They argue that variables also confound database compilations of expression profiles, and that the most promising use in the near future would be to clarify pathways for the various types of toxicity and carcinogenicity and get biomarkers for these pathways, to help assess relevance of nonclinical findings to humans. [1a, 3a]

41. Jain KK. Cancer biomarkers: current issues and future directions. Curr Opin Mol Ther. 2007;9:563-71. [pmid: 18041667].

This paper reviews cancer biomarkers and their role in understanding the pathobiological mechanisms of cancer as well as providing targets for drug discovery. It also examines the characteristics of an ideal cancer biomarker (summarized in Table 2) and emerging technologies for biomarker detection. The authors particularly focus on the use of biomarkers for anticancer drug development and clinical applications, including determination of prognosis as well as monitoring of response to therapy. The authors suggest that a major challenge in development of cancer biomarkers is that a number of genes are up- and down-regulated in cancer, making it problematic to rely on any single tumor biomarker even for one type of cancer. They argue that the physiological properties of the microenvironment of a majority (90 percent) of tumors, such as hypoxia, acidity, and changes in temperature, are considered promising environmental markers for tumor targeting. [2a, 2b, 3b]

42. Katz R. Biomarkers and surrogate markers: an FDA perspective. NeuroRx. 2004;1:189-195. [pmid: 15717019].

This article discusses the regulatory context and epistemological problems related to the interpretation of clinical trials in which unvalidated surrogate markers are used as primary outcomes. While the current law and regulations permit the FDA to base the approval of a drug product on a determination the effect of the drug on an unvalidated surrogate marker, there are a number of difficulties in interpreting trials that use surrogate markers as primary measures of drug effect. The author argues that because our knowledge of the relevant pharmacologic and biologic events is always imperfect/incomplete, drugs are typically approved on the simple finding of a beneficial effect in clinical trials (and on adequate safety data). This is ideal, he argues, not only because it is a direct clinical benefit that is obviously desired by the patient, but also because waiting to fully understand the relevant biologic events before drugs are approved is an undesirable strategy. This is why approval of a drug on the basis of an effect on an unvalidated surrogate marker represents such a fundamental departure from the typical course of action in drug approval. That is, approval of a drug on the basis of such an effect presupposes knowledge of events that is normally not only absent, but, in a sense, irrelevant. Because we do not ever have all of this knowledge, approval based on effects on surrogate markers will invariably involve a level of uncertainty not typical of the more standard route to drug approval. [1a, 3a, 3b, 3c]

43. Kelloff GJ, Sigman CC. New science-based endpoints to accelerate oncology drug development. Eur J Cancer. 2005;41:491-501. [pmid: 15737552].

This paper presents definitions and classifications of biomarkers for use in oncology drug development. Recent progress along with advances in imaging and bioassay technologies are the basis for describing and evaluating new biomarker endpoints as well as for defining other biomarkers for identifying patient populations, potential toxicity, and providing evidence of drug effect and efficacy. Science-based and practical criteria for validating biomarkers have been developed including considerations of mechanistic plausibility, available methods and technology, and clinical feasibility. For BMEBM purposes, these criteria for mechanistic plausibility—summarized in Table 3—are most relevant. [1a, 3a, 3b]

44. Kluft C. Principles of use of surrogate markers and endpoints. Maturitas. 2004;47:293-8. [pmid: 15063482].

The author of this paper—concerned with the validation of candidate surrogate end-points for the cardiovascular risk of sex steroids — contends that surrogate end-points are markers of biological mechanisms and require a mechanistic view on diseases. The validation process for venous thromboembolic disease and arterial disease biomarkers requires that a separate evaluation be made of the multiple clinical endpoints in which different biological mechanisms are likely to operate. Sex steroids have many effects on biological mechanisms and the selection and validation of surrogates from the changes in multiple mechanisms is a large enterprise. [1a, 3c]

45. Krishna R, Herman G, Wagner JA. Accelerating drug development using biomarkers: a case study with sitagliptin, a novel DPP4 inhibitor for type 2 diabetes. AAPS J. 2008;10:401-9. [pmid: 18686043].

In this review, applications of proximal (target engagement) and distal (disease-related) biomarkers are highlighted using the example of the recent development of sitagliptin for type 2 diabetes. The authors suggest that elucidation of target engagement and disease-related biomarkers significantly accelerated sitagliptin drug development, and facilitated design of clinical trials while streamlining dose focus and optimization, the net impact of which reduced overall cycle time to filing as compared to the industry average. [1a, 3c]

46. Kuhlmann J, Wensing G. The applications of biomarkers in early clinical drug development to improve decision-making processes. Curr Clin Pharmacol. 2006;1:185-91. [pmid: 18666370].

In this paper, the author contends that biomarkers are most useful in the early phase of clinical development when measurement of clinical endpoints or true surrogates may be too time-consuming or cumbersome to provide timely proof of principle or dose-ranging information. The use of biomarkers in early drug development helps to streamline clinical development by determining whether the drug is reaching and affecting the molecular target in humans, delivering findings that are comparable to preclinical data, and by providing a measurable endpoint that predicts desired or undesired clinical effects. Critical decisions such as candidate selection, early proof of mechanism or proof of concept, dose ranging and patient stratification as well as the assessment of development risks regarding safety, toxicity and drug interactions can be based on measurement of appropriate biomarkers that are biologically and/or clinically validated. Preclinical and phase I development plans can be focused to support an early biomarker study in healthy volunteers or mildly diseased patients, thus saving both resources and time. Dose estimates and patient stratification may reduce the size and duration of clinical studies in later phases of development, and safety and toxicity biomarkers may help to stop or continue a program early on. Even if a biomarker fails in the validation process there may still be a benefit of having used it as more knowledge about pathophysiology of the disease and the drug may be obtained. [1a, 3a, 3b, 3c, 6]

47. Kumar S, Mohan A, Guleria R. Biomarkers in cancer screening, research and detection: present and future: a review. Biomarkers. 2006;11:385-405. [pmid: 16966157].

This review describes the development of biomarkers in cancer research and detection with emphasis on different proteomic tools for the identification and discovery of new biomarkers, different clinical assays to detect various biomarkers in different specimens, role of biomarkers in cancer screening and the challenges in this direction of cancer research. Biomarkers offer a means for homogeneous classification of a disease and risk factor, and can extend basic information about the underlying pathogenesis of disease. The goals in cancer research include finding biomarkers that can be used for the early detection of cancers, design individual therapies, and to identify underlying processes involved in the disease. The author suggests that because so many myriad processes are involved in the diseased states, the goal is similar to finding a needle in a haystack. However, the development of ‘omic technologies, has allowed us to monitor a large number of key cellular pathways simultaneously. This has enabled the identification of biomarkers and signaling molecules associated with cell growth, cell death and cellular metabolism, and are also facilitating in monitoring the functional disturbance, molecular and cellular damage, and damage response. Table 3 (characteristics of an ideal screening program) and Table 5 (characteristics of an ideal biomarker) are particularly relevant for BMEBM purposes. [1a, 3a, 3c]

48. Kurian S, Grigoryev Y, Head S, et al. Applying genomics to organ transplantation medicine in both discovery and validation of biomarkers. Int Immunopharmacol. 2007;7:1948-60. [pmid: 18039531].

This paper examines the development of biomarkers in the area of organ transplantation. The authors state that the life and death nature of end stage organ failure, the severe donor organ shortage, and the powerful and toxic drug therapies required for the lifetimes of transplant patients, require biomarkers as tools to diagnose disease in its early stages, predict prognosis, suggest treatment options and then assist in the implementation of therapies. The article usefully highlights 2 broad approaches to biomarker discovery: (1) a hypothesis-driven approach in which a candidate molecule provides the target for which a biomarker is developed, and (2) looking for combinations or relatively large panels of biomarkers to diagnose disease conditions. The authors largely eschew the former approach for mechanistic reasons (e.g., complex interplay of many pathways, cascades and networks of molecules; cells or tissues interactions with neighboring cells that can trigger various cellular responses at a distant site). The authors argue that a single molecule or several in a single network cannot possibly direct and regulate these complex responses. Interestingly, they endorse the latter approach, which explores complex molecular networks and significantly increases the dimensionality of biomarker discovery using genomic technologies. This is an agnostic approach that eliminates the need to identify targets based a priori on specific biological knowledge of mechanisms and associations. [1a, 1b, 2a, 2b, 3a]

49. Kyzas PA, Denaxa-Kyza D, Ioannidis JP. Almost all articles on cancer prognostic markers report statistically significant results. Eur J Cancer. 2007;43:2559-79. [pmid: 17981458].

This study reviewed a meta-analysis and individual articles concerning cancer prognostic biomarkers and found that published articles almost ubiquitously highlighted significant prognostic associations. In the rare articles where no prognostic markers were presented as significant, authors often presented other (nonprognostic) statistically significant analyses, expanded on the importance of nonsignificant trends, or defended the importance of the cancer marker with other arguments. Entirely ‘negative’ articles on prognostic cancer markers represented less than 1.5 percent of this literature. The authors conclude that under strong reporting bias, statistical significance loses its discriminating ability for the importance of prognostic markers. [1a]

50. Lassere MN. The Biomarker-Surrogacy Evaluation Schema: a review of the biomarker-surrogate literature and a proposal for a criterion-based, quantitative, multidimensional hierarchical levels of evidence schema for evaluating the status of biomarkers as surrogate endpoints. Stat Methods Med Res. 2008;17:303-40. [pmid: 17925313].

51. Lassere MN, Johnson KR, Boers M, et al. Definitions and validation criteria for biomarkers and surrogate endpoints: development and testing of a quantitative hierarchical levels of evidence schema. J Rheumatol. 2007;34:607-15. [pmid: 17343307].

In the above two articles, Lassere and collegues report on their efforts to develop a levels of evidence schema to evaluate biomarker and surrogate research. In the 2007 article, Lassere et al. propose a “variables in medicine” continuum. The lowest end is a large pool of biomarkers which are indicators of biological, pathological, or genetic disease development, or are a reflection of the mechanism of therapeutic interventions. As one moves forward on the continuum, the “variables container” becomes smaller when one considers only biomarkers that are validated clinical correlates or risk/prognostic factors. Then the “variables container” is narrowed further for the collection of surrogate endpoints. The highest end of the continuum consists only of very few outcomes which can be deemed as clinical endpoints in clinical trials. These endpoints reflect how a patient feels, functions, or survives. The constriction process of the “medical variable pool” is guided by the strength of the linkage of the biomarkers to the clinical endpoint, and by how confidently the biomarker can represent the clinical endpoint. The validation of risk/prognostic factors requires the demonstration of strong patient-level correlation only between the biomarker and the clinical endpoint.

This 2008 article represents a minor refinement of the above approach, now named the Biomarker-Surrogacy Evaluation Schema. The schema incorporates the three independent domains: Study Design, Target Outcome and Statistical Evaluation. Each domain has items ranked from0 to 5. The total score (0–15) determines the level of evidence, with Level 1 the strongest and Level 5 the weakest. The term “surrogate” is restricted to markers attaining Levels 1 or 2 only. Surrogacy status of markers can then be directly compared within and across different areas of medicine to guide individual, trial-based or drug-development decisions. [1a, 3a, 3c]

52. Lathia CD, Amakye D, Dai W, et al. The value, qualification, and regulatory use of surrogate end points in drug development. Clin Pharmacol Ther. 2009;86:32-43. [pmid: 19474783].

This article reviews the history of the development, qualification, and acceptance of nine surrogate endpoints. The authors argue that both the successes and failures had three key characteristics: (i) apparent biologic plausibility, (ii) prognostic value for the outcome of the disease, and (iii) an association between changes in the surrogates and changes in outcome with therapeutic intervention. With regard to biologic plausibility, the authors concluded that there was not sufficient evidence to make plausibility an absolute requirement for surrogate status, as the strength of plausibility did not appear to discriminate between the successes and the failures. They further argued that: “There is also a downside to making plausibility a requirement: new molecular ‘signature’ biomarkers that are identified by complex mathematical and statistical methods will not necessarily have initial plausibility that can be understood in conventional terms. Although concerns about unknown plausibility with such ‘black-box’ markers could lead to an increased requirement for more prognostic and/or clinical outcome linkage data, we would not seek to block them from surrogate status or other advanced regulatory use merely because we cannot mechanistically explain why they work, as long as their utility is tested in practice.” This article may be an especially useful touchstone for BMEBM thinking re: biomarkers and surrogates. [1a, 3a, 3c]

53. Lavallie ER, Dorner AJ, Burczynski ME. Use of ex vivo systems for biomarker discovery. Curr Opin Pharmacol. 2008;8:647-53. [pmid: 18771752].

This review article addresses the uses of ex vivo systems for both disease tissues and surrogate normal tissues to provide mechanistic insights into drug action and for the purpose of identifying candidate biomarkers. The authors make the case that biomarkers that either indicate PD effects or constitute predictive measures of individual patient responses can support dose selection and/or help determine therapeutic options. The development of biomarkers for clinical testing and validation can be facilitated by the use of ex vivo systems utilizing clinically relevant human tissues for the discovery of biomarkers of drug activity before first in human studies. Ex vivo analyses of tumors, liver tissue or hepatocytes, skin, and chondrocytes are discussed. [2b]

54. Lee JW, Figeys D, Vasilescu J. Biomarker assay translation from discovery to clinical studies in cancer drug development: quantification of emerging protein biomarkers. Adv Cancer Res. 2007;96:269-98. [pmid: 17161683].

This chapter discusses the challenges faced during cancer biomarker discovery as well as during technology and process translation, including pre-analytical planning, assay development, and preclinical and clinical validation. Particularly useful for BMEBM purposes is Figure 1, which describes intertwined processes of drug development and biomarker development. The horizontal blocks in the figure depict the progression of drug development of a new chemical or biological entity with unconfirmed mechanism of action. The drug development uses multiple biomarkers in various purposes from efficacy/safety assessment, down to market differentiation. The vertical blocks depict the developmental processes of moving a novel biomarker of unconfirmed mechanism to proof of biology, and to surrogacy. The processes include biomarker selection of on- and off-target markers, method development, validation, and application. [1a, 3a, 3b, 3c]

55. Lesko LJ. Paving the critical path: how can clinical pharmacology help achieve the vision?. Clin Pharmacol Ther. 2007;81:170-7. [pmid: 17259944].

This article discusses the FDA’s Critical Path Initiative (CPI) and the role of clinical pharmacologists in the drug development process. It includes a discussion of model-based, semi-mechanistic drug development, drug/disease models that facilitate informed clinical trial designs and optimal dosing, the qualification process and criteria for new biomarkers and surrogate endpoints. Interestingly, the author argues that the CPI requires a paradigm shift from empiric to mechanistic thinking to improve the efficiency, predictiveness, and informativeness of clinical drug development. This shift, he argues, is driven by more precise biological and molecular definitions of disease phenotypes where traditional diseases are being subdivided into different subtypes. This, in turn, can lead to more targeted treatments with significantly improved benefit/risk ratios. Figures 2 and 3 in the paper—flowcharts describing key questions and qualification processes for biomarkers—may be useful for BMEBM purposes. [1a, 3a, 3b]

56. Lock EA, Bonventre JV. Biomarkers in translation; past, present and future. Toxicology. 2008;245:163-6. [pmid: 18272278].

This paper discusses the history of the discovery of biomarkers for renal and cardiac injury. The authors summarize the use of biomarkers in preclinical evaluation in experimental animals and in patients to help diagnose or monitor a disease, predict outcome or to evaluate a therapeutic intervention. [2a, 3b]

57. Lonn E. The use of surrogate endpoints in clinical trials: focus on clinical trials in cardiovascular diseases. Pharmacoepidemiol Drug Saf. 2001;10:497-508. [pmid: 11828831].

This review provides a definition of surrogate endpoints, proposes practical criteria for establishing their validity, outlines some of the advantages, disadvantages and specific statistical considerations associated with their use in clinical trials and attempts to also highlight drug approval issues associated with the use of these endpoints. A number of examples are also provided related to the use of surrogate endpoints in clinical trials with special emphasis on their use in cardiovascular medicine. [1a, 3c]

58. Marrer E, Dieterle F. Biomarkers in oncology drug development: rescuers or troublemakers?. Expert Opin Drug Metab Toxicol. 2008;4:1391-402. [pmid: 18950281].

59. Marrer E, Dieterle F. Promises of biomarkers in drug development—a reality check. Chem Biol Drug Des. 2007;69:381-94. [pmid: 17581232].

The above two articles discuss different types of biomarkers, their identification, validation and use in different phases of drug development from drug discovery, to approval, to clinical application, as well as the state-of-the-art biomarker technologies and promising future methods. Though they do not offer great insight into key questions raised by BMEBM, they provide a useful overview of the state of the field, and address some economic considerations that that affect biomarker development and implementation. [1a]

60. McMichael AJ, Hall AJ. The use of biological markers as predictive early-outcome measures in epidemiological research. IARC Sci Publ. 1997:281-9. [pmid: 9354927].

This article examines the uses of biomarkers in epidemiological research as early-outcome measures to predict the occurrence of clinical disease and to elucidate the biological mechanism of pathogenesis. The authors suggest that the proposed epidemiological use is conceptually less straightforward than the well-established use of biomarkers to improve or extend exposure assessment or to study inter-individual variations in disease susceptibility. In principle, they argue that this form of use could accelerate or facilitate etiological research. The authors suggest that this mode of biomarker use, especially in cancer epidemiology, is the least clear-cut and the least well developed. The recurrent problem is identifying biomarkers that: (1) are on the causal pathway, (2) have a high probability of progression to clinical disease, and (3) account for all or most of the cases of the specified clinical outcome. Such biomarkers would be most useful if they conferred a long lead-time relative to clinical disease occurrence. [1a, 3a, 3b]

61. Merlo DF, Sormani MP, Bruzzi P. Molecular epidemiology: new rules for new tools?. Mutat Res. 2006;600:3-11. [pmid: 16843503].

The authors of this article begin by defining molecular epidemiology as a field that “combines biological markers and epidemiological observations in the study of the environmental and genetic determinants of cancer and other diseases.” They argue that there are many advantages associated with incorporating biomarkers into epidemiologic research, including: (1) increased sensitivity and specificity to carcinogenic exposures; (2) more precise evaluation of the interplay between genetic and environmental determinants of cancer; (3) earlier detection of carcinogenic effects of exposure; (4) characterization of disease subtypes-etiologies patterns; (5) evaluation of primary prevention measures. They suggest that an area that has not received sufficient attention concerns the validation of these biomarkers as surrogate endpoints for cancer risk. Of particular relevance to BMEBM is the authors’ contention that the challenges posed by the application of validation principles to epidemiological research, where the basic tool for this validation (i.e., the randomized study) is seldom possible, have not been thoroughly explored. They examine a number of observational study designs that may help to address this challenge. This article provides a good companion piece to McMichael and Hall (1997). [1a, 3a, 3b]

62. Oldenhuis CN, Oosting SF, Gietema JA, et al. Prognostic versus predictive value of biomarkers in oncology. Eur J Cancer. 2008;44:946-53. [pmid: 18396036].

This article seeks to clarify differences between prognostic and predictive cancer biomarkers. The authors contend that the best prognostic factors are still simple clinical parameters (e.g., performance status, number of metastatic sites, tumor grade), and that prognostic biomarkers might be useful for hypothesis testing for their relevance as predictive markers, as targets for therapy and for the selection of patients for adjuvant treatment. A predictive factor is used upfront to predict response to therapy or is monitored during treatment to define the effectiveness of this treatment. They argue that predictive biomarkers are needed that can guide patient tailored therapy as knowledge of biological mechanisms of tumors and evidence of their heterogeneity and multi-factorial nature grows. Most studies only contribute low levels of evidence due to retrospective data and small sample size, and many reports lack sufficient information to be compared to other studies. The authors believe that there is an urgent need for prospective data to validate hypotheses and it is therefore of great importance that biomarker analyses are incorporated into randomized clinical trials as a separate objective. [1a, 3a]

63. Park JW, Kerbel RS, Kelloff GJ, et al. Rationale for biomarkers and surrogate end points in mechanism-driven oncology drug development. Clin Cancer Res. 2004;10:3885-96. [pmid: 15173098].

This article highlights the potential, as well as the associated challenges, of using mechanism-based biomarkers to facilitate the development of molecular targeted therapies. The authors contend that targeting drugs to molecularly defined populations is difficult to implement and has not been a traditional approach in the development of new drugs. By providing insight into disease mechanisms and interactions with therapy, the successful implementation of biomarkers can significantly advance the effort to rationally develop targeted agents. Case studies of trastuzumab, imatinib, EGFR inhibitors and angiogenesis inhibitors are examined. [3a, 3c]

64. Pepe MS, Etzioni R, Feng Z, et al. Phases of biomarker development for early detection of cancer. J Natl Cancer Inst. 2001;93:1054-61. [pmid: 11459866].

The purpose of this article is to define a formal structure to guide the process of biomarker development. The authors categorize the development into five phases that a biomarker needs to pass through to produce a useful population-screening tool. The phases of research are generally ordered according to the strength of evidence that each provides in favor of the biomarker, from weakest to strongest. The five phases are: Phase 1—Preclinical Exploratory Studies; Phase 2—Clinical Assay and Validation; Phase 3—Retrospective Longitudinal Repository Studies; Phase 4—Prospective Screening Studies; and Phase 5—Cancer Control Studies. As the authors note, evidential criteria for when a biomarker can reasonably progress from one phase of development to the next was not included in their proposal, and require multidisciplinary panels of experts for their definition. The authors make clear that their proposal is not meant to be rigid or definitive; rather it a foundation for dialogue that will ultimately lead to improved rigor in biomarker research. [1a, 3a]

65. Psaty BM, Lumley T. Surrogate end points and FDA approval: a tale of 2 lipid-altering drugs. JAMA. 2008;299:1474-6. [pmid: 18364491].

66. Psaty BM, Weiss NS, Furberg CD, et al. Surrogate end points, health outcomes, and the drug-approval process for the treatment of risk factors for cardiovascular disease. JAMA. 1999;282:786-90. [pmid: 10463718].

The above two articles examine surrogate end point approaches to the drug approval process in the treatment of cardiovascular disease. At issue is the need to balance the public health advantages of rapid approval for drugs that turn out to be safe and effective against harms that might occur when drugs approved on the basis of surrogate end points turn out later either to have significant safety problems or to lack efficacy.

The 1999 article examines the advantages and disadvantages of using surrogates to assess therapies. The authors state that reliance on surrogates raises the possibility of incomplete, inadequate, or misleading evaluations, stating: “To use only a surrogate end point is to accept as empirical evidence for clinical practice a hypothesis about health benefits that has never been tested.” They offer two proposals for reforming the drug approval process.

The 2008 article examines recent experience with two lipid-altering drugs, ezetimibe and torcetrapib. The authors argue that the rapid FDA approval and aggressive marketing of ezetimibe before RCTs were underway exposed patients to unnecessary risks. By contrast, an RCT for torcetrapib was underway before FDA approval, and the trial was stopped early because of an increase in the risk of the primary end point, major cardiovascular events. [1a, 3c]

67. Ransohoff DF. Evaluating discovery-based research: when biologic reasoning cannot work. Gastroenterology. 2004;127:1028. [pmid: 15480977].

This brief editorial makes the emphatic point that, in the area of the new ‘omics technologies, questions about biological plausibility — namely questions in the form of “Should it work?”—are off-target. Rather, the question about whether something does or does not work can be settled–and must be settled– by a different kind of reasoning. This form of reasoning requires direct observation and comparison by using research methods that rigorously avoid chance and bias as alternate explanations for results. The author argues that problems of chance and bias are primarily the domain not of biologic reasoning but of epidemiologic reasoning. [1a]

68. Ransohoff DF. Rules of evidence for cancer molecular-marker discovery and validation. Nat Rev Cancer. 2004;4:309-14. [pmid: 15057290].

69. Ransohoff DF. Bias as a threat to the validity of cancer molecular-marker research. Nat Rev Cancer. 2005;5:142-9. [pmid: 15685197].

70. Ransohoff DF. How to improve reliability and efficiency of research about molecular markers: roles of phases, guidelines, and study design. J Clin Epidemiol. 2007;60:1205-19. [pmid: 17998073].

71. Ransohoff DF. Promises and limitations of biomarkers. Recent Results Cancer Res. 2009;181:55-9. [pmid: 19213557].

The above four articles examine the promise and limitations of the ‘omics technologies in the area of cancer biomarker development. The author draws an interesting distinction between drug discovery and biomarker discovery research. Drug research typically proceeds through prospective randomized and blinded studies that make comparisons between treated and nontreated subjects, and so, in the author’s words, “tends to involve generally reliable studies.” Biomarker studies (for markers of prognosis or diagnosis) are observational, and “are routinely threatened by serious bias.” As such, the author repeatedly beats the drum in support of investigators learning to understand the sources of bias affecting biomarker studies and how to approach them. Researchers often rely on tools such as “phases” and “guidelines” to facilitate communication and collaboration (see Pepe 2001), believing that they provide thorough prescriptions for conducting clinical research. The author believes that these tools are limited, and that much greater attention should be paid to study design (the details that constitute the substance of the actual planning, conduct, and interpretation of a research study) of each individual study. [1a, 3b]

72. Ratain MJ, Glassman RH. Biomarkers in phase I oncology trials: signal, noise, or expensive distraction?. Clin Cancer Res. 2007;13:6545-8. [pmid: 18006752].

This is an editorial commentary in response to the meta-analysis by Goulart et al. (2007). Although the authors take issue with the operational definition of biomarker Goulart et al. use and raise other limitations of their study, they accept Goulart at al.’s conclusions that the use of biomarkers in Phase I oncology studies is not warranted at this time. [1a]

73. Shi Q, Sargent DJ. Meta-analysis for the evaluation of surrogate endpoints in cancer clinical trials. Int J Clin Oncol. 2009;14:102-11. [pmid: 19390940].

This article addresses general issues and challenges surrounding surrogate endpoints in cancer clinical trials. The authors review various meta-analytic methodologies concerning the application of these methods to cancer clinical trials with different tumor types. In oncology, several applications have successfully identified useful surrogates (e.g., disease-free survival and progression-free survival as surrogates for overall survival in advanced colorectal cancer). They also discuss several limitations of surrogate endpoints, including issues related to the extrapolation of the validity of a surrogate. They suggest that the success of the surrogate is very likely to depend on specific individual mechanisms of the treatment, and caution that the extrapolation of the validity of one surrogate into different disease populations, interventions with different biological pathways, and sometimes even only different dose levels, may not be appropriate. The authors contend that before applying a surrogate endpoint in a trial, the benefit-risk tradeoff should always be examined thoroughly, based on historical clinical trial results and new evidence available. [1a, 3c]

74. Sinha A, Singh C, Parmar D, et al. Proteomics in clinical interventions: achievements and limitations in biomarker development. Life Sci. 2007;80:1345-54. [pmid: 17210164].

This review article examines achievements and limitations of proteomics in developing predictive biomarkers for toxicological and clinical interventions. They authors contend that proteomics is providing insights into the mechanism of action of a wide range of substances and is being used to increase speed and sensitivity of toxicological screening by identifying toxicity and efficacy biomarkers. The major challenges, they argue, are the discrimination of changes due to inter-individual variation, experimental background noise in protein profiling, and post-translational modifications. Despite intensive research, only a very limited number of plasma proteins have been validated as biomarkers for disease. Although proteome approaches have provided opportunities to define molecular mechanisms of toxicity and clinical interventions, reproducibility in expression depends on experimental conditions across different laboratories and, therefore, remains a challenge for the field. [1a, 3a]

75. Sistare FD, Dieterle F, Troth S, et al. Towards consensus practices to qualify safety biomarkers for use in early drug development. Nat Biotechnol. 2010;28:446-54. [pmid: 20458314].

This article describes core principles, mutual decisions, and unresolved issues which emerged in the course of the Predictive Safety Testing Consortium’s efforts to qualify seven new safety biomarkers of drug-induced renal injury to support regulatory decision-making during early drug development. They articulate a number of strength-of-evidence criteria for evaluating safety biomarkers, including: biological plausibility of the association of the biomarkers with injury to the organ of interest; understanding of the molecular mechanism of the biomarker response; strong association of changes in biomarker levels to pathological outcomes and superior performance relative to currently accepted biomarkers; and consistent response across mechanistically diverse toxicants, sexes, strains, and species (see Box 1). The article does a nice job in articulating the scientific and economic challenges of qualifying biomarkers, making the case for establishing a consortium of stakeholders from industry, academia and regulatory bodies. [1a, 3a, 6]

76. Tan DS, Thomas GV, Garrett MD, et al. Biomarker-driven early clinical trials in oncology: a paradigm shift in drug development. Cancer J. 2009;15:406-20. [pmid: 19826361].

This article provides an overview of biomarkers in early clinical trials, including examples where they have been particularly successful, and the caveats and pitfalls associated with indiscriminate application. The authors describe the use of PD endpoints to demonstrate the proof of modulation of target, pathway, and biologic effect, as well as predictive biomarkers for patient selection and trial enrichment. They contend that accurate preclinical models are important for PK-PD-efficacy modeling and biomarker validation. The degree of scientific and analytical validation should ensure that biomarkers are fit-for purpose, according to the stage of development and the impact on the trial; specifically they are either exploratory or used to make decisions within the trial. To be maximally useful at an early stage, these must be in place before the commencement of phase I trials. Validation and qualification of biomarkers then continues through clinical development. The authors highlight the impact of technology platforms such as genomics, proteomics, circulating tumor cells, and minimally invasive functional and molecular imaging, with respect to their potential role in improving the success rate and speed of drug development and in interrogating the consequences of therapeutic intervention and providing unique insights into human disease biology. [1a, 2a, 3a]

77. Taube SE, Clark GM, Dancey JE, et al. A perspective on challenges and issues in biomarker development and drug and biomarker codevelopment. J Natl Cancer Inst. 2009;101:1453-63. [pmid: 19855077].

This article reports the issues discussed and recommendations issued from a 2007 workshop sponsored by the National Cancer Institute and the US Food and Drug Administration concerning past lessons learned and ongoing challenges faced in biomarker development and drug and biomarker codevelopment. Figure 1 of the paper presents a useful schematic of the considerations addressed, including evidence/understanding of biological mechanism. According to the authors, a recurring theme in the workshop’s discussions was the need to increase understanding of the biology associated with the chosen biomarkers, including their role in tumor behavior and their interplay with the drugs ’ mechanisms of action. This biological understanding should be integrated into the clinical context in which the biomarker would be used (see case studies of HER2 and EGFR summarized in Boxes 1 and 2, respectively). “Biological rationale” is described as a key factor in selecting candidate predictive biomarkers for codevelopment with a cancer therapeutic. This would include evidence that the biomarker(s) chosen is meaningfully correlated with the activity of the targeted agent. The evidence may derive from existing preclinical and clinical literature; data collected during phase I, expanded phase II, or early phase III clinical studies of the agent; or modeling and biological inferences using incomplete or partially complete provisional datasets and data mining. All available information on cellular pathways relevant to drug action, mechanisms, or drug interactions should be included in decision making and in generation of study hypotheses. The authors make clear that some of the major challenges for biomarker assay and therapeutic agent codevelopment relate to the costs of standardizing and evaluating the utility of an assay when neither the clinical activity of the agent nor the relationship of the biomarker to the mechanism(s) of action of the agent being developed is clear. [1a, 2a, 2b, 3a]

78. Temple R. Are surrogate markers adequate to assess cardiovascular disease drugs?. JAMA. 1999;282:790-5. [pmid: 10463719].

In this article, the author makes the case that to become surrogates biomarkers need to be correlated with outcome in clinical trials of more than one drug with the same mechanism of action targeted at the same indication. See Table 1 for factors related to biological plausibility that either favor or do not favor candidate surrogates. [1a, 3c]

79. Trusheim MR, Berndt ER, Douglas FL. Stratified medicine: strategic and economic implications of combining drugs and clinical biomarkers. Nat Rev Drug Discov. 2007;6:287-93. [pmid: 17380152].

This article examines current and emerging examples in which therapies are matched with specific patient population characteristics using clinical biomarkers (which the authors call “stratified medicine”) and discusses the implications of this approach to future drug development strategies and market opportunities. The authors suggest that “differential biological mechanism” is a necessary condition for stratified medicine, claiming that at least one of the following biological characteristics with the potential to differentiate patients must exist: (1) underlying disease variability reflecting multi-factorial etiology, or currently indistinguishable clinical presentations for biologically distinct conditions; (2) multiple relevant targets for medical intervention; (3) differential ADME (absorption, distribution, metabolism and excretion) characteristics, toxicity or tolerability of the therapeutic regimen(s); and (4) adaptiveness of the disease leading to treatment resistance. [1a, 3a, 3b]

80. van Gool AJ, Henry B, Sprengers ED. From biomarker strategies to biomarker activities and back. Drug Discov Today. 2010;15:121-6. [pmid: 19931413].

This review outlines the rational question-based drug development strategy in which biomarker data drive decisions on which drug candidates to progress to clinical testing. The authors cite the high attrition rates during clinical development, arguing that the major cause for this high attrition is the proof-of-concept phase, during which the attrition rate is as high as 80 percent because of a lack of efficacy and/or unacceptable safety liabilities. This leads them to surmise that preclinical studies in pharmaceutical research are insufficient to predict drug action in patients. The authors then proceed to outline their “question-based” drug development approach, which includes a number of mechanistic considerations. One question included in their approach is: “Does the compound cause its intended pharmacological and functional effects?” Most drugs inhibit or stimulate their target, with downstream functional consequences. To verify that the drug has the same effect on the pathway in patients as in the preceding cellular or animal models, clinically applicable biomarkers indicative of signaling pathways are required. For example, for a kinase drug target active in blood cells, one can monitor the phosphorylated substrates and/or downstream gene and protein expression patterns. If the drug is found not to modulate its mechanism of action in patients, one can decide to switch to an improved drug candidate. If the drug does modulate the mechanism as predicted but there is no effect on disease parameters, the concept of targeting this drug target in these patients can be abandoned. [1a, 3a, 3b]

81. Verma M, Srivastava S. New cancer biomarkers deriving from NCI early detection research. Recent Results Cancer Res. 2003;163:72-84. discussion 264–6. [pmid: 12903844].

82. Verma M, Wright GLJ, Hanash SM, et al. Proteomic approaches within the NCI early detection research network for the discovery and identification of cancer biomarkers. Ann N Y Acad Sci. 2001;945:103-15. [pmid: 11708463].

The above two articles discuss the efforts of the Early Detection Research Network at the National Cancer Institute, in bringing together scientific expertise from leading national and international institutions, to identify and validate biomarkers for the detection of precancerous and cancerous cells in determining risk for developing cancer. Other topics covered include the use of genomics and proteomics as high-throughput technology platforms to facilitate biomarker-aided detection of early cancer, and issues surrounding the analysis, validation, and predictive value of biomarkers using such technologies. [1a, 2b, 3a]

83. Vineis P, Perera F. Molecular epidemiology and biomarkers in etiologic cancer research: the new in light of the old. Cancer Epidemiol Biomarkers Prev. 2007;16:1954-65. [pmid: 17932342].

84. Vineis P, Porta M. Causal thinking, biomarkers, and mechanisms of carcinogenesis. J Clin Epidemiol. 1996;49:951-6. [pmid: 8780601].

The above two articles explore how the use of biomarkers should be considered within the context of causal models in epidemiology, and of the intertwining of causation and pathogenesis. The authors indicate that the use of biomarkers is increasing both in acute and chronic disease epidemiology, but the rationale for their introduction is not always firmly established. Unlike infectious diseases, for cancer and cardiovascular disease external “necessary” causes have not been identified. Thus, the classification of cancer and other chronic diseases cannot be based on unequivocal criteria such as the “etiologic” classification of infectious diseases. From a mechanistic point of view, unless molecular biology discovers specific mechanistic steps in carcinogenesis, which indicate the existence of “necessary” events in carcinogenesis, we cannot adopt an unequivocal definition of cancer. The authors argue that the potential contribution of biomarkers to the elucidation of the pathogenetic process should be considered in the light of such uncertainties. There is a range of indications for biomarkers, from the use of very specific measurements aimed at single molecules, to measurements indicating cumulative exposure to agents with the same mechanism of action. The potential uses of markers in chronic disease epidemiology include: exposure assessment in cases in which traditional epidemiologic tools are insufficient; multiple exposures or mixtures, in which the aim is to disentangle the etiologic role of single agents; estimation of the total burden of exposure to chemicals having the same mechanistic target; and investigation of pathogenetic mechanisms. [1a, 3a, 3b]

85. Wagner JA. Overview of biomarkers and surrogate endpoints in drug development. Dis Markers. 2002;18:41-6. [pmid: 12364809].

86. Wagner JA, Williams SA, Webster CJ. Biomarkers and surrogate end points for fit-for-purpose development and regulatory evaluation of new drugs. Clin Pharmacol Ther. 2007;81:104-7. [pmid: 17186007].

87. Wagner JA. Strategic approach to fit-for-purpose biomarkers in drug development. Annu Rev Pharmacol Toxicol. 2008;48:631-51. [pmid: 17937595].

88. Wagner JA. Biomarkers: principles, policies, and practice. Clin Pharmacol Ther. 2009;86:3-7. [pmid: 19536113].

89. Wagner JA, Prince M, Wright EC, et al. The Biomarkers Consortium: practice and pitfalls of open-source precompetitive collaboration. Clin Pharmacol Ther. 2010;87:539-42. [pmid: 20407460].

The above five articles provide an account of fit-for-purpose biomarker qualification. Wagner and colleagues suggest that thinking of qualification in terms of stages offers a useful way to understand the relationship between evidence evaluation and utility for decision-making. On this account, biomarker qualification is a graded, fit-for-purpose evidentiary process linking a biomarker with biological processes and clinical endpoints, dependent on the intended application. Biomarkers used in drug development can be categorized into four classes of qualification: (a) Exploration biomarkers are research and development tools accompanied by in vitro and/or preclinical evidence, but with no consistent information linking the biomarker clinical outcomes in humans; (b) demonstration biomarkers are associated with adequate preclinical sensitivity and specificity and are linked with clinical outcomes, but have not been reproducibly demonstrated in clinical studies; (c) characterization biomarkers are associated with adequate preclinical sensitivity and specificity and are reproducibly linked to clinical outcomes in more than one prospective clinical study in humans; and (d ) surrogacy reflects a holistic evaluation of the available data, demonstrating that the biomarker can substitute for a clinical endpoint. Observational data collected from clinical settings can also provide critical information in the qualification process, linking mechanistic data at the molecular level to population-level findings. This schema captures the increasing decision-making and regulatory utility of biomarkers as qualifying evidence is accrued. [1a, 2a, 3a, 3b, 3c]

90. Williams SA, Slavin DE, Wagner JA, et al. A cost-effectiveness approach to the qualification and acceptance of biomarkers. Nat Rev Drug Discov. 2006;5:897-902. [pmid: 17080026].

The authors of this article take the view that given the absence of widely accepted and practically applicable criteria that facilitate adequate biomarker qualification, cost-effectiveness considerations should be brought to bear on the evaluation of biomarkers. They assess existing qualification schemas and conclude that each is too subjective to achieve wide acceptance among a diverse set of stakeholders. They articulate a set of principles that enable cost-effectiveness evaluations of biomarkers even with incomplete knowledge (see Box 1). [1a]

91. Woodcock J. Chutes and ladders on the critical path: comparative effectiveness, product value, and the use of biomarkers in drug development. Clin Pharmacol Ther. 2009;86:12-4. [pmid: 19536116].

92. Woodcock J, Woosley R. The FDA critical path initiative and its influence on new drug development. Annu Rev Med. 2008;59:1-12. [pmid: 18186700].

The above two articles describe the FDA’s Critical Path Initiative with respect to the role of biomarkers and biomarker qualification. Emphasis is placed on the need to foster public-private partnerships and consortia of experts in order to ensure that evaluation occurs in a timely and rigorous manner. [1a]

93. Zhao L, Jin W, Rader D, et al. A Translational Medicine perspective of the development of torcetrapib: Does the failure of torcetrapib development cast a shadow on future development of lipid modifying agents, HDL elevation strategies or CETP as a viable molecular target for atherosclerosis? A case study of the use of biomarkers and Translational Medicine in atherosclerosis drug discovery and development. Biochem Pharmacol. 2009;78:315-25. [pmid: 19539799].

This article uses a case study of the failed development of torcetrapib to emphasize the need for a paradigm shift from the conventional drug development mode to a biomarker-based Translational Medicine (TMed) strategy. Although the relationship between HDL (high density lipoprotein) function and cardiovascular (CV) risk had been extensively explored, the premise that HDL elevation is linked to reduced CV risks and that high HDL cholesterol (HDL-C) might be a potential surrogate biomarker for reduced CV risk remains controversial. Substantial genetic, molecular, biochemical and preclinical evidence raised the hope that HDL-C elevation via cholesteryl ester transfer protein (CETP) inhibition might generate clinical benefits. However, four large-scale clinical trials with the CETP inhibitor torcetrapib failed to demonstrate benefits on CV clinical outcomes. Likewise, biomarkers that were supposed to predict vascular risk reduction provided disappointing results. Emergence of further CETP inhibitors encourage continued development of such compounds for cardiovascular risk management. However, there is a need to adopt biomarker-driven TMed strategies in target validation, target-compound interaction, PD activities, disease modification and patient selection to guide future drug development efforts. These strategies may elucidate multiple, complex pathways and help yield more compelling mechanistic evidence for the relationship between HDL and prevention of CHD. [1a, 2a, 2b, 3a, 3b]

## II Articles Retrieved But Not Annotated

### Category A: Added minimally to other information (i.e., limited or redundant)

1 Bast RCJ, Lilja H, Urban N, et al. Translational crossroads for biomarkers. Clin Cancer Res. 2005;11:6103-8. [pmid: 16144908].
2 Cavero I. Optimizing the preclinical/clinical interface: an Informa Life Sciences conference 12–13 December, 2006. Expert Opin Drug Saf. 2007;6:217-24. [pmid: 17367268].
3 Desai AA, Hysi P, Garcia JG. Integrating genomic and clinical medicine: searching for susceptibility genes in complex lung diseases. Transl Res. 2008;151:181-93. [pmid: 18355765].
4 Desar IM, van Herpen CM, van Laarhoven HW, et al. Beyond RECIST: molecular and functional imaging techniques for evaluation of response to targeted therapy. Cancer Treat Rev. 2009;35:309-21. [pmid: 19136215].
5 Duffy SW, Treasure FP. Potential surrogate endpoints in cancer research—some considerations and examples. Pharm Stat. 2011;10(1):34-9. [pmid: 20029937].
6 Fasolo A, Sessa C. Translational research in phase I trials. Clin Transl Oncol. 2009;11:580-8. [pmid: 19775997].
7 Levinson SS. Weak associations between prognostic biomarkers and disease in preliminary studies illustrates the breach between statistical significance and diagnostic discrimination. Clin Chim Acta. 2010;411:467-73. [pmid: 20083096].
8 Lin D, Hollander Z, Meredith A, et al. Searching for ‘omic’ biomarkers. Can J Cardiol. Suppl A. 2009;25:9A-14A.
9 Lockhart BP, Walther B. Biomarkers: “Found in translation”. Med Sci (Paris). 2009;25:423-30. [pmid: 19409197].
10 Moore RE, Kirwan J, Doherty MK, et al. Biomarker discovery in animal health and disease: the application of post-genomic technologies. Biomark Insights. 2007;2:185-96. [pmid: 19662203].
11 Nicolette CA, Miller GA. The identification of clinically relevant markers and therapeutic targets. Drug Discov Today. 2003;8:31-8. [pmid: 12546989].
12 Potter JD. Cancer prevention: epidemiology and experiment. Cancer Lett. 1997;114:7-9. [pmid: 9103244].
13 Richter WS. Imaging biomarkers as surrogate endpoints for drug development. Eur J Nucl Med Mol Imaging. Suppl 1. 2006;33:6-10. [pmid: 16721568].
14 Sawyers CL. The cancer biomarker problem. Nature. 2008;452:548-52. [pmid: 18385728].
15 Steele VE, Kelloff GJ. Development of cancer chemopreventive drugs based on mechanistic approaches. Mutat Res. 2005;591:16-23. [pmid: 16083917].
16 Warnock DG, Peck CC. A roadmap for biomarker qualification. Nat Biotechnol. 2010;28:444-5. [pmid: 20458313].

### Category B: Focused entirely on mechanisms of disease, with no attention to mechanisms of therapeutic interventions

### Category C: Article could not be located

1 Gimmi CD. Current stumbling blocks in oncology drug development. Ernst Schering Res Found Workshop. 2007:135-49. [C]. [pmid: 17117720].
2 Kelloff GJ, Boone CW, Crowell JA, et al. Surrogate endpoint biomarkers for phase II cancer chemoprevention trials. J Cell Biochem Suppl. 1994;19:1-9. [C]. [pmid: 7823579].
3 Kensler TW, Davidson NE, Groopman JD, et al. Biomarkers and surrogacy: relevance to chemoprevention. IARC Sci Publ. 2001;154:27-47. [C]. [pmid: 11220666].
4 Ryan NS, Fox NC. Imaging biomarkers in Alzheimer’s disease. Ann N Y Acad Sci. 2009;1180:20-7. [C]. [pmid: 19906257].
5 Strand KJ, Khalak H, Strovel JW, et al. Expression biomarkers for clinical efficacy and outcome prediction in cancer. Pharmacogenomics. 2006;7:105-15. [C]. [pmid: 16354128].
6 Vainio H. Promise of molecular epidemiology—epidemiologic reasoning, biological rationale and risk assessment. Scand J Work Environ Health. 1999;25:498-504. [C]. [pmid: 10884145].
7 Venitz J. Using exposure-response and biomarkers to streamline early drug development. Ernst Schering Res Found Workshop. 2007:47-63. [C]. [pmid: 17117714].

## III Mapping articles onto conceptual framework

1 Strength of evidence for existence of intervention’s pathway
  c Quality (design and execution) and strength (quantitative effect) of experimental evidence in preclinical models.
    - Altar (2008a, 2008b)
    - Alymani (2010)
    - Fine (2009)
    - Floyd (2004)
    - Glassman (2009)
    - Goodsaid (2007, 2008, 2010)
    - Goulart (2007)
    - Hampel (2004)
    - Hong (2010)
    - Hunter (2010)
    - Jacobs (2009)
    - Katz (2004)
    - Kelloff (2005)
    - Kluft (2004)
    - Krishna (2008)
    - Kuhlmann (2006)
    - Kumar (2006)
    - Kurian (2007)
    - Kyzas (2007)
    - Lassere (2007, 2008)
    - Lathia (2009)
    - Lee (2007)
    - Lesko (2007)
    - Lonn (2001)
    - McMichael (1997)
    - Merlo (2006)
    - Oldenhuis (2008)
    - Pepe (2001)
    - Psaty (1999, 2008)
    - Ransohoff (2004a, 2004b, 2005, 2007, 2009)
    - Ratain (2007)
    - Shi (2009)
    - Sinha (2007)
    - Sistare (2010)
    - Tan (2009)
    - Taube (2009)
    - Temple (1999)
    - Trusheim (2007)
    - van Gool (2010)
    - Verma (2001, 2003)
    - Vineis (1996, 2007)
    - Wagner (2002, 2007, 2008, 2009, 2010)
    - Williams (2006)
    - Woodcock (2008, 2009)
    - Zhao (2009)
  d Number of experimental models
    - Antoine (2009)
    - Kurian (2007)
  e Variety of experimental models (e.g., animal species)
    - Day (2008)
7 Strength of evidence that the pathway exists in human disease states.
  e Strength of evidence for animal/in vitro model’s relevance for human disease state.
    - Boffetta (2010)
    - Danhof (2005)
    - Danna (2006)
    - Day (2008)
    - Fleming (2005)
    - Floyd (2004)
    - Goodsaid (2007, 2008, 2010)
    - Jain (2007)
    - Kurian (2007)
    - Lock (2008)
    - Tan (2009)
    - Taube (2009)
    - Wagner (2002, 2007, 2008, 2009, 2010)
    - Zhao (2009)
  f Ex vivo evidence
    - Bhattacharya (2009)
    - Bhogal (2008)
    - Chau (2008)
    - Clark (2009)
    - Coate (2009)
    - Collins (2006)
    - Danna (2006)
    - Dhani (2008)
    - Dudley (2009)
    - Hampel (2004)
    - Hong (2010)
    - Hunter (2010)
    - Jain (2007)
    - Kurian (2007)
    - Lavallie (2008)
    - Taube (2009)
    - Verma (2001, 2003)
    - Wagner (2002, 2007, 2008, 2009, 2010)
    - Zhao (2009)
  g Evidence that pathway occurs in complete physiologic system (e.g., functioning hearts vs. heart tissue.)
  h Evidence from human physiologic experiments.
8 Completeness of proposed mechanistic pathway. (From intervention to clinical endpoint)
  a. Gaps in pathway (including whether intervention/exposure can exert effect on target due to issues of bioavailability, metabolism, delivery, etc.)
    - Alymani (2010)
    - Antoine (2009)
    - Boffetta (2010)
    - Carden (2009)
    - Chau (2008)
    - Chetty (2010)
    - Coate (2009)
    - Colburn (2000, 2003)
    - Danna (2006)
    - Day (2008, 2009)
    - Fine (2009)
    - Floyd (2004)
    - Frank (2003)
    - Glassman (2009)
    - Goodsaid (2007, 2008, 2010)
    - Goulart (2007)
    - Hampel (2004)
    - Hunter (2010)
    - Jacobs (2009)
    - Katz (2004)
    - Kelloff (2005)
    - Kuhlmann (2006)
    - Kumar (2006)
    - Kurian (2007)
    - Lassere (2007, 2008)
    - Lathia (2009)
    - Lee (2007)
    - Lesko (2007)
    - McMichael (1997)
    - Merlo (2006)
    - Oldenhuis (2008)
    - Park (2004)
    - Pepe (2001)
    - Sinha (2007)
    - Sistare (2010)
    - Tan (2009)
    - Taube (2009)
    - Trusheim (2007)
    - van Gool (2010)
    - Verma (2001, 2003)
    - Vineis (1996, 2007)
    - Wagner (2002, 2007, 2008, 2009, 2010)
    - Zhao (2009)
  b. Remoteness of the mechanistic outcomes from clinical outcomes.
    - BDWG (2001)
    - Carroll (2007)
    - Clark (2009)
    - Colburn (2000, 2003)
    - Collins (2006)
    - Day (2009)
    - Dhani (2008)
    - Frank (2003)
    - Glassman (2009)
    - Gollob (2006)
    - Goodsaid (2007, 2008, 2010)
    - Jain (2007)
    - Katz (2004)
    - Kelloff (2005)
    - Kuhlmann (2006)
    - Lee (2007)
    - Lesko (2007)
    - Lock (2008)
    - McMichael (1997)
    - Merlo (2006)
    - Ransohoff (2004b, 2005, 2007, 2009)
    - Trusheim (2007)
    - van Gool (2010)
    - Vineis (1996, 2007)
    - Wagner (2002, 2007, 2008, 2009, 2010)
    - Zhao (2009)
  c. Strength of evidence linking proximal (i.e., surrogate) to distal (i.e., definitive) clinical endpoints
    - Altar (2008a, 2008b)
    - Alymani (2010)
    - Bhattacharya (2009)
    - Bhogal (2008)
    - BDWG (2001)
    - Boffetta (2010)
    - Carroll (2007)
    - Colburn (2000, 2003)
    - Danhof (2005)
    - De Gruttola (2001)
    - Fine (2009)
    - Fleming (1996)
    - Fleming (2005)
    - Frank (2003)
    - Gollob (2006)
    - Hurko (2009)
    - Katz (2004)
    - Kluft (2004)
    - Krishna (2008)
    - Kuhlmann (2006)
    - Kumar (2006)
    - Lassere (2007, 2008)
    - Lathia (2009)
    - Lee (2007)
    - Lonn (2001)
    - Park (2004)
    - Psaty (1999, 2008)
    - Shi (2009)
    - Temple (1999)
- Evidence for alternate, competing or compensatory pathways that can:
  a. Produce outcome through pathways independent of intervention’s effect
  b. Produce nontherapeutic outcomes through pathways dependent on intervention
  c. Interfere with intervention’s pathways
- Strength of evidence that mechanism is similar to other interventions with known clinical effects
  - BDWG (2001)
- Adverse effect mechanisms
  - Antoine (2009)
  - Chetty (2010)
  - Hurko (2009)
  - Kuhlmann (2006)
  - Sistare (2010)

## Appendix B References

Altar CA, Bounos D, Amakye D, et al. A prototypical process for creating evidentiary standards for biomarkers and diagnostics. Clin Pharmacol Ther. Feb. 2008;83(2):368-71. [pmid: 18091762].
Altar CA. The Biomarkers Consortium: on the critical path of drug discovery. Clin Pharmacol Ther. Feb. 2008;83(2):361-4. [pmid: 18183037].
Alymani NA, Smith MD, Williams DJ, et al. Predictive biomarkers for personalised anti-cancer drug use: Discovery to clinical implementation. Eur J Cancer. Mar. 2010;46(5):869-79. [pmid: 20138504].
Antoine DJ, Mercer AE, Williams DP, et al. Mechanism-based bioanalysis and biomarkers for hepatic chemical stress. Xenobiotica. 2009;39:565-77. [pmid: 19621999].
Bast RCJ, Lilja H, Urban N, et al. Translational crossroads for biomarkers. Clin Cancer Res. 2005;11:6103-8. [pmid: 16144908].
Bhattacharya S, Mariani TJ. Array of hope: expression profiling identifies disease biomarkers and mechanism. Biochem Soc Trans. 2009;37:855-62. [pmid: 19614607].
Bhogal N, Balls M. Translation of new technologies: from basic research to drug discovery and development. Curr Drug Discov Technol. 2008;5:250-62. [pmid: 18690893].
Biomarker Definitions Working Group. Biomarkers and surrogate endpoints: preferred definitions and conceptual framework. Clin Pharmacol Ther. Mar. 2001;69(3):89-95. [pmid: 11240971].
Boffetta P. Biomarkers in cancer epidemiology: an integrative approach. Carcinogenesis. 2010;31:121-6. [pmid: 19959558].
Carden CP, Banerji U, Kaye SB, et al. From darkness to light with biomarkers in early clinical trials of cancer drugs. Clin Pharmacol Ther. 2009;85:131-3. [pmid: 19151637].
Carroll KJ. Biomarkers in drug development: friend or foe? A personal reflection gained working within oncology. Pharm Stat. 2007;6:253-60. [pmid: 17351904].
Cavero I. Optimizing the preclinical/clinical interface: an Informa Life Sciences conference 12–13 December, 2006. Expert Opin Drug Saf. 2007;6:217-24. [pmid: 17367268].
Chau CH, Rixe O, McLeod H, et al. Validation of analytic methods for biomarkers used in drug development. Clin Cancer Res. 2008;14:5967-76. [pmid: 18829475].
Chetty RK, Ozer JS, Lanevschi A, et al. A systematic approach to preclinical and clinical safety biomarker qualification incorporating Bradford Hill’s principles of causality association. Clin Pharmacol Ther. Aug. 2010;88(2):260-2. [pmid: 20592723].
Clark DP. Ex vivo biomarkers: functional tools to guide targeted drug development and therapy. Expert Rev Mol Diagn. 2009;9:787-94. [pmid: 19895224].
Coate LE, John T, Tsao MS, et al. Molecular predictive and prognostic markers in non-small-cell lung cancer. Lancet Oncol. 2009;10:1001-10. [pmid: 19796752].
Colburn WA. Biomarkers in drug discovery and development: from target identification through drug marketing. J Clin Pharmacol. 2003;43:329-41. [pmid: 12723454].
Colburn WA. Optimizing the use of biomarkers, surrogate endpoints, and clinical endpoints for more efficient drug development. J Clin Pharmacol. 2000;40:1419-27. [pmid: 11185662].
Collins CD, Purohit S, Podolsky RH, et al. The application of genomic and proteomic technologies in predictive, preventive and personalized medicine. Vascul Pharmacol. 2006;45:258-67. [pmid: 17030152].
Danhof M, Alvan G, Dahl SG, et al. Mechanism-based pharmacokinetic-pharmacodynamic modeling-a new classification of biomarkers. Pharm Res. 2005;22:1432-7. [pmid: 16132354].
Danna EA, Nolan GP. Transcending the biomarker mindset: deciphering disease mechanisms at the single cell level. Curr Opin Chem Biol. 2006;10:20-7. [pmid: 16406766].
Day M, Balci F, Wan HI, et al. Cognitive endpoints as disease biomarkers: optimizing the congruency of preclinical models to the clinic. Curr Opin Investig Drugs. 2008;9:696-706.
Day M, Rutkowski JL, Feuerstein GZ. Translational medicine—a paradigm shift in modern drug discovery and development: the role of biomarkers. Adv Exp Med Biol. 2009;655:1-12. [pmid: 20047030].
De Gruttola VG, Clax P, DeMets DL, et al. Considerations in the evaluation of surrogate endpoints in clinical trials. Summary of a National Institutes of Health workshop. Control Clin Trials. 2001;22:485-502. [pmid: 11578783].
Desai AA, Hysi P, Garcia JG. Integrating genomic and clinical medicine: searching for susceptibility genes in complex lung diseases. Transl Res. 2008;151:181-93. [pmid: 18355765].
Desar IM, van Herpen CM, van Laarhoven HW, et al. Beyond RECIST: molecular and functional imaging techniques for evaluation of response to targeted therapy. Cancer Treat Rev. 2009;35:309-21. [pmid: 19136215].
Dhani N, Siu LL. Clinical trials and biomarker development with molecularly targeted agents and radiotherapy. Cancer Metastasis Rev. 2008;27:339-49. [pmid: 18379730].
Dudley JT, Butte AJ. Identification of discriminating biomarkers for human disease using integrative network biology. Pac Symp Biocomput. 2009:27-38. [pmid: 19209693].
Duffy SW, Treasure FP. Potential surrogate endpoints in cancer research—some considerations and examples. Pharm Stat. 2009.
Fasolo A, Sessa C. Translational research in phase I trials. Clin Transl Oncol. 2009;11:580-8. [pmid: 19775997].
Fine BM, Amler L. Predictive biomarkers in the development of oncology drugs: a therapeutic industry perspective. Clin Pharmacol Ther. 2009;85:535-8. [pmid: 19295504].
Fleming TR. Surrogate endpoints and FDA’s accelerated approval process. Health Aff (Millwood). 2005;24:67-78. [pmid: 15647217].
Fleming TR, DeMets DL. Surrogate end points in clinical trials: are we being misled?. Ann Intern Med. 1996;125:605-13. [pmid: 8815760].
Floyd E, McShane TM. Development and use of biomarkers in oncology drug development. Toxicol Pathol. Suppl 1. 2004;32:106-15. [pmid: 15209410].
Frank R, Hargreaves R. Clinical biomarkers in drug discovery and development. Nat Rev Drug Discov. 2003;2:566-80. [pmid: 12838269].
Gimmi CD. Current stumbling blocks in oncology drug development. Ernst Schering Res Found Workshop. 2007:135-49. [pmid: 17117720].
Glassman RH, Ratain MJ. Biomarkers in early cancer drug development: limited utility. Clin Pharmacol Ther. 2009;85:134-5. [pmid: 19151638].
Gollob JA, Bonomi P. Historic evidence and future directions in clinical trial therapy of solid tumors. Oncology (Williston Park). 2006;20:10-8. [pmid: 16773840].
Goodsaid F, Frueh F. Biomarker qualification pilot process at the U.S. Food and Drug Administration. AAPS J. 2007;9:E105-8. [pmid: 17408233].
Goodsaid F, Papaluca M. Evolution of biomarker qualification at the health authorities. Nat Biotechnol. 2010;28:441-3. [pmid: 20458312].
Goodsaid FM, Frueh FW, Mattes W. Strategic paths for biomarker qualification. Toxicology. 2008;245:219-23. [pmid: 18280028].
Goulart BH, Clark JW, Pien HH, et al. Trends in the use and role of biomarkers in phase I oncology trials. Clin Cancer Res. 2007;13:6719-26. [pmid: 18006773].
Hampel H, Mitchell A, Blennow K, et al. Core biological marker candidates of Alzheimer’s disease—perspectives for diagnosis, prediction of outcome and reflection of biological activity. J Neural Transm. 2004;111:247-72. [pmid: 14991453].
Hong H, Goodsaid F, Shi L, et al. Molecular biomarkers: a US FDA effort. Biomark Med. 2010;4:215-25. [pmid: 20406066].
Hunter DJ, Losina E, Guermazi A, et al. A pathway and approach to biomarker validation and qualification for osteoarthritis clinical trials. Curr Drug Targets. 2010;11:536-45. [pmid: 20199395].
Hurko O. The uses of biomarkers in drug development. Ann N Y Acad Sci. 2009;1180:1-10. [pmid: 19906255].
Jacobs A. An FDA perspective on the nonclinical use of the X-Omics technologies and the safety of new drugs. Toxicol Lett. 2009;186:32-5. [pmid: 18809476].
Jain KK. Cancer biomarkers: current issues and future directions. Curr Opin Mol Ther. 2007;9:563-71. [pmid: 18041667].
Katz R. Biomarkers and surrogate markers: an FDA perspective. NeuroRx. 2004;1:189-195. [pmid: 15717019].
Kelloff GJ, Boone CW, Crowell JA, et al. Surrogate endpoint biomarkers for phase II cancer chemoprevention trials. J Cell Biochem Suppl. 1994;19:1-9. [pmid: 7823579].
Kelloff GJ, Sigman CC. New science-based endpoints to accelerate oncology drug development. Eur J Cancer. 2005;41:491-501. [pmid: 15737552].
Kensler TW, Davidson NE, Groopman JD, et al. Biomarkers and surrogacy: relevance to chemoprevention. IARC Sci Publ. 2001;154:27-47. [pmid: 11220666].
Kluft C. Principles of use of surrogate markers and endpoints. Maturitas. 2004;47:293-8. [pmid: 15063482].
Krishna R, Herman G, Wagner JA. Accelerating drug development using biomarkers: a case study with sitagliptin, a novel DPP4 inhibitor for type 2 diabetes. AAPS J. 2008;10:401-9. [pmid: 18686043].
Kuhlmann J, Wensing G. The applications of biomarkers in early clinical drug development to improve decision-making processes. Curr Clin Pharmacol. 2006;1:185-91. [pmid: 18666370].
Kumar S, Mohan A, Guleria R. Biomarkers in cancer screening, research and detection: present and future: a review. Biomarkers. 2006;11:385-405. [pmid: 16966157].
Kurian S, Grigoryev Y, Head S, et al. Applying genomics to organ transplantation medicine in both discovery and validation of biomarkers. Int Immunopharmacol. 2007;7:1948-60. [pmid: 18039531].
Kyzas PA, Denaxa-Kyza D, Ioannidis JP. Almost all articles on cancer prognostic markers report statistically significant results. Eur J Cancer. 2007;43:2559-79. [pmid: 17981458].
Lassere MN. The Biomarker-Surrogacy Evaluation Schema: a review of the biomarker-surrogate literature and a proposal for a criterion-based, quantitative, multidimensional hierarchical levels of evidence schema for evaluating the status of biomarkers as surrogate endpoints. Stat Methods Med Res. 2008;17:303-40. [pmid: 17925313].
Lassere MN, Johnson KR, Boers M, et al. Definitions and validation criteria for biomarkers and surrogate endpoints: development and testing of a quantitative hierarchical levels of evidence schema. J Rheumatol. 2007;34:607-15. [pmid: 17343307].
Lathia CD, Amakye D, Dai W, et al. The value, qualification, and regulatory use of surrogate end points in drug development. Clin Pharmacol Ther. 2009;86:32-43. [pmid: 19474783].
Lavallie ER, Dorner AJ, Burczynski ME. Use of ex vivo systems for biomarker discovery. Curr Opin Pharmacol. 2008;8:647-53. [pmid: 18771752].
Lee JW, Figeys D, Vasilescu J. Biomarker assay translation from discovery to clinical studies in cancer drug development: quantification of emerging protein biomarkers. Adv Cancer Res. 2007;96:269-98. [pmid: 17161683].
Lesko LJ. Paving the critical path: how can clinical pharmacology help achieve the vision?. Clin Pharmacol Ther. 2007;81:170-7. [pmid: 17259944].
Levinson SS. Weak associations between prognostic biomarkers and disease in preliminary studies illustrates the breach between statistical significance and diagnostic discrimination. Clin Chim Acta. 2010;411:467-73. [pmid: 20083096].
Lin D, Hollander Z, Meredith A, et al. Searching for ‘omic’ biomarkers. Can J Cardiol. Suppl A. 2009;25:9A-14A.
Lock EA, Bonventre JV. Biomarkers in translation; past, present and future. Toxicology. 2008;245:163-6. [pmid: 18272278].
Lockhart BP, Walther B. Biomarkers: “Found in translation”. Med Sci (Paris). 2009;25:423-30. [pmid: 19409197].
Lonn E. The use of surrogate endpoints in clinical trials: focus on clinical trials in cardiovascular diseases. Pharmacoepidemiol Drug Saf. 2001;10:497-508. [pmid: 11828831].
Malkesman O, Austin DR, Chen G, et al. Reverse translational strategies for developing animal models of bipolar disorder. Dis Model Mech. 2009;2:238-45. [pmid: 19407332].
Marrer E, Dieterle F. Biomarkers in oncology drug development: rescuers or troublemakers?. Expert Opin Drug Metab Toxicol. 2008;4:1391-402. [pmid: 18950281].
Marrer E, Dieterle F. Promises of biomarkers in drug development—a reality check. Chem Biol Drug Des. 2007;69:381-94. [pmid: 17581232].
McMichael AJ, Hall AJ. The use of biological markers as predictive early-outcome measures in epidemiological research. IARC Sci Publ. 1997:281-9. [pmid: 9354927].
Merlo DF, Sormani MP, Bruzzi P. Molecular epidemiology: new rules for new tools?. Mutat Res. 2006;600:3-11. [pmid: 16843503].
Moore RE, Kirwan J, Doherty MK, et al. Biomarker discovery in animal health and disease: the application of post-genomic technologies. Biomark Insights. 2007;2:185-96. [pmid: 19662203].
Nicolette CA, Miller GA. The identification of clinically relevant markers and therapeutic targets. Drug Discov Today. 2003;8:31-8. [pmid: 12546989].
Oldenhuis CN, Oosting SF, Gietema JA, et al. Prognostic versus predictive value of biomarkers in oncology. Eur J Cancer. 2008;44:946-53. [pmid: 18396036].
Park JW, Kerbel RS, Kelloff GJ, et al. Rationale for biomarkers and surrogate end points in mechanism-driven oncology drug development. Clin Cancer Res. 2004;10:3885-96. [pmid: 15173098].
Pepe MS, Etzioni R, Feng Z, et al. Phases of biomarker development for early detection of cancer. J Natl Cancer Inst. 2001;93:1054-61. [pmid: 11459866].
Potter JD. Cancer prevention: epidemiology and experiment. Cancer Lett. 1997;114:7-9. [pmid: 9103244].
Psaty BM, Lumley T. Surrogate end points and FDA approval: a tale of 2 lipid-altering drugs. JAMA. 2008;299:1474-6. [pmid: 18364491].
Psaty BM, Weiss NS, Furberg CD, et al. Surrogate end points, health outcomes, and the drug-approval process for the treatment of risk factors for cardiovascular disease. JAMA. 1999;282:786-90. [pmid: 10463718].
Ransohoff DF. Bias as a threat to the validity of cancer molecular-marker research. Nat Rev Cancer. 2005;5:142-9. [pmid: 15685197].
Ransohoff DF. Evaluating discovery-based research: when biologic reasoning cannot work. Gastroenterology. 2004;127:1028. [pmid: 15480977].
Ransohoff DF. How to improve reliability and efficiency of research about molecular markers: roles of phases, guidelines, and study design. J Clin Epidemiol. 2007;60:1205-19. [pmid: 17998073].
Ransohoff DF. Promises and limitations of biomarkers. Recent Results Cancer Res. 2009;181:55-9. [pmid: 19213557].
Ransohoff DF. Rules of evidence for cancer molecular-marker discovery and validation. Nat Rev Cancer. 2004;4:309-14. [pmid: 15057290].
Ratain MJ, Glassman RH. Biomarkers in phase I oncology trials: signal, noise, or expensive distraction?. Clin Cancer Res. 2007;13:6545-8. [pmid: 18006752].
Richter WS. Imaging biomarkers as surrogate endpoints for drug development. Eur J Nucl Med Mol Imaging. Suppl 1. 2006;33:6-10. [pmid: 16721568].
Ryan NS, Fox NC. Imaging biomarkers in Alzheimer’s disease. Ann N Y Acad Sci. 2009;1180:20-7. [pmid: 19906257].
Sawyers CL. The cancer biomarker problem. Nature. 2008;452:548-52. [pmid: 18385728].
Shi Q, Sargent DJ. Meta-analysis for the evaluation of surrogate endpoints in cancer clinical trials. Int J Clin Oncol. 2009;14:102-11. [pmid: 19390940].
Sinha A, Singh C, Parmar D, et al. Proteomics in clinical interventions: achievements and limitations in biomarker development. Life Sci. 2007;80:1345-54. [pmid: 17210164].
Sistare FD, Dieterle F, Troth S, et al. Towards consensus practices to qualify safety biomarkers for use in early drug development. Nat Biotechnol. 2010;28:446-54. [pmid: 20458314].
Steele VE, Kelloff GJ. Development of cancer chemopreventive drugs based on mechanistic approaches. Mutat Res. 2005;591:16-23. [pmid: 16083917].
Strand KJ, Khalak H, Strovel JW, et al. Expression biomarkers for clinical efficacy and outcome prediction in cancer. Pharmacogenomics. 2006;7:105-15. [pmid: 16354128].
Tan DS, Thomas GV, Garrett MD, et al. Biomarker-driven early clinical trials in oncology: a paradigm shift in drug development. Cancer J. 2009;15:406-20. [pmid: 19826361].
Taube SE, Clark GM, Dancey JE, et al. A perspective on challenges and issues in biomarker development and drug and biomarker codevelopment. J Natl Cancer Inst. 2009;101:1453-63. [pmid: 19855077].
Temple R. Are surrogate markers adequate to assess cardiovascular disease drugs?. JAMA. 1999;282:790-5. [pmid: 10463719].
Trusheim MR, Berndt ER, Douglas FL. Stratified medicine: strategic and economic implications of combining drugs and clinical biomarkers. Nat Rev Drug Discov. 2007;6:287-93. [pmid: 17380152].
Vainio H. Promise of molecular epidemiology—epidemiologic reasoning, biological rationale and risk assessment. Scand J Work Environ Health. 1999;25:498-504. [pmid: 10884145].
van Gool AJ, Henry B, Sprengers ED. From biomarker strategies to biomarker activities and back. Drug Discov Today. 2010;15:121-6. [pmid: 19931413].
Venitz J. Using exposure-response and biomarkers to streamline early drug development. Ernst Schering Res Found Workshop. 2007:47-63. [pmid: 17117714].
Verma M, Srivastava S. New cancer biomarkers deriving from NCI early detection research. Recent Results Cancer Res. 2003;163:72-84. discussion 264–6. [pmid: 12903844].
Verma M, Wright GLJ, Hanash SM, et al. Proteomic approaches within the NCI early detection research network for the discovery and identification of cancer biomarkers. Ann N Y Acad Sci. 2001;945:103-15. [pmid: 11708463].
Vineis P, Perera F. Molecular epidemiology and biomarkers in etiologic cancer research: the new in light of the old. Cancer Epidemiol Biomarkers Prev. 2007;16:1954-65. [pmid: 17932342].
Vineis P, Porta M. Causal thinking, biomarkers, and mechanisms of carcinogenesis. J Clin Epidemiol. 1996;49:951-6. [pmid: 8780601].
Wagner JA. Biomarkers: principles, policies, and practice. Clin Pharmacol Ther. 2009;86:3-7. [pmid: 19536113].
Wagner JA. Overview of biomarkers and surrogate endpoints in drug development. Dis Markers. 2002;18:41-6. [pmid: 12364809].
Wagner JA. Strategic approach to fit-for-purpose biomarkers in drug development. Annu Rev Pharmacol Toxicol. 2008;48:631-51. [pmid: 17937595].
Wagner JA, Prince M, Wright EC, et al. The Biomarkers Consortium: practice and pitfalls of open-source precompetitive collaboration. Clin Pharmacol Ther. 2010;87:539-42. [pmid: 20407460].
Wagner JA, Williams SA, Webster CJ. Biomarkers and surrogate end points for fit-for-purpose development and regulatory evaluation of new drugs. Clin Pharmacol Ther. 2007;81:104-7. [pmid: 17186007].
Warnock DG, Peck CC. A roadmap for biomarker qualification. Nat Biotechnol. 2010;28:444-5. [pmid: 20458313].
Williams SA, Slavin DE, Wagner JA, et al. A cost-effectiveness approach to the qualification and acceptance of biomarkers. Nat Rev Drug Discov. 2006;5:897-902. [pmid: 17080026].
Woodcock J. Chutes and ladders on the critical path: comparative effectiveness, product value, and the use of biomarkers in drug development. Clin Pharmacol Ther. 2009;86:12-4. [pmid: 19536116].
Woodcock J, Woosley R. The FDA critical path initiative and its influence on new drug development. Annu Rev Med. 2008;59:1-12. [pmid: 18186700].
Zhao L, Jin W, Rader D, et al. A Translational Medicine perspective of the development of torcetrapib: Does the failure of torcetrapib development cast a shadow on future development of lipid modifying agents, HDL elevation strategies or CETP as a viable molecular target for atherosclerosis? A case study of the use of biomarkers and Translational Medicine in atherosclerosis drug discovery and development. Biochem Pharmacol. 2009;78:315-25. [pmid: 19539799].