# Results

We performed our assessment of predictive validity for 9 CERs, which together included almost 150 individual conclusions. For each CER, we present a table of summary data about the concordance of individual conclusions (Tables 3–11). The full table with each conclusion and how it was assessed is presented in the appendix. We also present an overall table that sums up the individual conclusion assessments across all CERs (Table 12).

Table 3 Concordance of predicted and actual conclusions for update of Comparative Effectiveness of Management Strategies for Gastroesophageal Reflux Disease (GERD)

Conclusion | Good | Fair | Poor
Still valid | 4 | | 1
Possibly out of date | 1
Probably out of date | 1
Out of date | | 4

Not applicable/No matching conclusions/New conclusions = 2

Table 4 Concordance of predicted and actual conclusions for update of Effectiveness of Noninvasive Diagnostic Tests for Breast Abnormalities

Conclusion | Good | Fair | Poor
Still valid | 1
Possibly out of date | 1 | 1
Probably out of date | 1
Out of date

Table 5 Concordance of predicted and actual conclusions for update of Comparative Effectiveness of Epoetin and Darbepoetin for Managing Anemia in Patients Undergoing Cancer Treatment

Conclusion | Good | Fair | Poor
Still valid | 1
Possibly out of date | 1 | 1
Probably out of date | 2
Out of date | 1

Not applicable/No matching conclusions/New conclusions = 3

Table 6 Concordance of predicted and actual conclusions for update of Comparative Effectiveness and Safety of Analgesics for Osteoarthritis

Conclusion | Good | Fair | Poor
Still valid | 19
Possibly out of date | 2 | 2
Probably out of date | 1
Out of date | 2

Table 7 Concordance of predicted and actual conclusions for update of Efficacy and Comparative Effectiveness of Off-Label Use of Atypical Antipsychotics

Conclusion | Good | Fair | Poor
Still valid | 16 | 1
Possibly out of date | 2
Probably out of date | 1
Out of date

Not applicable/No matching conclusions/New conclusions = 2

Table 8 Concordance of predicted and actual conclusions for update of Comparative Effectiveness of Drug Therapy for Rheumatoid Arthritis and Psoriatic Arthritis in Adults

Conclusion | Good | Fair | Poor
Still valid | 11
Possibly out of date | 2 | 2
Probably out of date | 1
Out of date | 1

Not applicable/No matching conclusions/New conclusions = 2

Table 9 Concordance of predicted and actual conclusions for update of Comparative Effectiveness of Treatments to Prevent Fractures in Men and Women with Low Bone Density or Osteoporosis

Conclusion | Good | Fair | Poor
Still valid | 27
Possibly out of date | 1 | 3
Probably out of date
Out of date

Not applicable/No matching conclusions/New conclusions = 12

Table 10 Concordance of predicted and actual conclusions for update of Comparative Effectiveness of Second-Generation Antidepressants in the Pharmacologic Treatment of Adult Depression

Conclusion | Good | Fair | Poor
Still valid | 13
Possibly out of date | | 7
Probably out of date
Out of date

Not applicable/No matching conclusions/New conclusions = 2

Table 11 Concordance of predicted and actual conclusions for update of Comparative Effectiveness of Angiotensin-Converting Enzyme Inhibitors (ACEIs) and Angiotensin II Receptor Antagonists (ARBs) for Treating Essential Hypertension

Conclusion | Good | Fair | Poor
Still valid | 7
Possibly out of date | 1
Probably out of date
Out of date

Table 12 Summary of concordance of predicted and actual conclusions across nine CERs

Conclusion | Good | Fair | Poor
Still valid | 83 | 1 | 1
Possibly | 11 | 16 | 0
Probably | 7 | 0 | 0
Out of date | 4 | 4 | 0

Not applicable/No matching conclusions/New conclusions = 22

The great majority of conclusions in each CER and across CERs had good concordance, except the CER about gastroesophageal reflux disease where four “out of date” conclusions had only fair concordance and one “still valid” conclusion was shown to be out of date. The first circumstance concerned endoscopic treatment for GERD, and the judgment in 2009 was that the conclusion should be “deleted” since the endoscopic procedures had been withdrawn from the market. But one of the three endoscopic procedures in the original report persisted, and new endoscopic procedures were introduced, and one of the two withdrawn procedures was later re-introduced. The update report noted this changing landscape, and we deemed the concordance only “fair” with the 2009 prediction. The surveillance signal would have been more appropriate saying the conclusion needed updating since the endoscopic procedures were evolving over time.

The instance where an individual conclusion that was rated as “still valid” but had poor concordance concerned surgery versus medical therapy for GERD. The original report concluded that the evidence showed these to be “similarly effective.” The update report concluded surgery was favored over medical therapy. One of the studies providing new evidence in support of this conclusion was published in 2009, after the surveillance signal search was done.

Table 13 presents our assessment of the global summary assessment of the priority for having needed an update, and the original priority for updating. One CER whose 2009 prediction was high priority was judged to have been a medium priority for updating based on the updated report. One medium priority update was judged as having been a high priority for an update. The remaining seven CERs had the same priority in both assessments. Table 14 presents the results of the overall assessment of priority for updating as a 2×2 table. The kappa statistic for agreement was 0.74.

Table 13 Comparison of predicted with actual priority for updating

CER | 2009 Prediction | End Date of Update Search | 2013 Assessment | Rationale
Comparative Effectiveness of Management Strategies for Gastroesophageal Reflux Disease | High | August 2010 | High | Some procedures specifically mentioned in the ES have been withdrawn from the market. New procedures have been introduced. There is a major change in the conclusion about surgery vs. medical therapy.
Effectiveness of Noninvasive Diagnostic Tests for Breast Abnormalities | High | September 2010 | Medium | The new data did not change the overall conclusions very much. The conclusion that MRI and ultrasound may be sufficient to evaluate lesions in women at low risk may be an important new conclusion.
Comparative Effectiveness of Epoetin and Darbepoetin for Managing Anemia in Patients Undergoing Cancer Treatment | High | April 2012 | High | Major safety concerns leading to substantial changes in black box warnings and practice guidelines.
Comparative Effectiveness and Safety of Analgesics for Osteoarthritis | High | January 2011 | High | ES specifically mentions a number of drugs that have been withdrawn due to safety concerns.
Efficacy and Comparative Effectiveness of Off-Label Use of Atypical Antipsychotic | Medium | May 2011 | Medium | Many new off-label indications and data on effectiveness, but these do not indicate strong effects of these drugs.
Comparative Effectiveness of Drug Therapy for Rheumatoid Arthritis and Psoriatic Arthritis in Adults | Medium | February 2011 | High | New expensive biologic DMARDs which feature prominently in the executive summary. Note: A surveillance on the JRA update report done in May 2013 identified new biologic agents as a “high” priority signal for another update.
Comparative Effectiveness of Treatments To Prevent Fractures in Men and Women With Low Bone Density or Osteoporosis | Medium | March 2011 | Medium | There are two new drugs, zoledronic acid and denosumab. However, there is no evidence that they are any more effective than existing drugs. There are signals of serious but rare new side effects, in particular subtrochanteric fractures of the hip, but not sufficient to change the initial decisions to recommend anti-resorptive therapy for osteoporotic women.
Comparative Effectiveness of Second-Generation Antidepressants in the Pharmacologic Treatment of Adult Depression | Low | January 2011 | Low | No substantive changes in conclusions.
Comparative Effectiveness of Angiotensin-Converting Enzyme Inhibitors (ACEIs) and Angiotensin II Receptor Antagonists (ARBs) for Treating Essential Hypertension | Low | December 2010 | Low | No substantive changes in conclusions.

Table 14 Predictive validity of priority for updating a systematic review^*^

Priority Based on Actual Changes in Conclusion
| High–2013 assessment | Medium–2013 assessment | Low–2013 assessment | Overall
High–2009 prediction | 3 | 1 | 0 | 4
Medium–2009 prediction | 1 | 2 | 0 | 3
Low–2009 prediction | 0 | 0 | 2 | 2
Total | 4 | 3 | 2 | 9

* Kappa=0.74