# References

1 Shekelle PG, Newberry SJ, Wu H, et al. Identifying Signals for Updating Systematic Reviews: A Comparison of Two Methods. Methods Research Report. AHRQ Publication No. 11-EHC042-EF. Rockville, MD. Agency for Healthcare Research and Quality. June. 2011. [pmid: 21834176].
2 Chung M, Newberry SJ, Ansari MT, et al. Two methods provide similar signals for the need to update systematic reviews. J Clin Epidemiol. Jun. 2012;65(6):660-8. [pmid: 22464414].
3 Newberry SJ, Ahmadzai N, Motala A, et al. Surveillance and Identification of Signals for Updating Systematic Review: Implementation and Early Experience. Methods Research Report. (Prepared by the RAND Corporation, Southern California Evidence-based Practice Center under Contract No. 290-2007-10062-I and University of Ottawa Evidence-based Practice Center 290-2007-10059-I). AHRQ Publication No. 13-EHC088-EF. Rockville, MD. Agency for Healthcare Research and Quality. May. 2013. www.effectivehealthcare.ahrq.gov/reports/final.cfm.
4 Shojania KG, Sampson M, Ansari MT, Ji J, Doucette S, Moher D. How quickly do systematic reviews go out of date? A survival analysis. Ann Intern Med. Aug. 21. 2007;147(4):224-33. [pmid: 17638714].
5 Peterson K, McDonagh MS, Fu R. Decisions to update comparative drug effectiveness reviews vary based on type of new evidence. J Clin Epidemiol. Sep. 2011;64(9):977-84. [pmid: 21411283].
6 Shekelle PG, Newberry SJ, Maglione M, et al. Assessment of the Need to Update Comparative Effectiveness Reviews: Report of an Initial Rapid Program Assessment (2005-2009). (Prepared by the Southern California Evidence-based Practice Center). Rockville, MD. Agency for Healthcare Research and Quality. October. 2009. www.effectivehealthcare.ahrq.gov/ehc/products/125/331/2009_0923UpdatingReports.pdf.
7 Hlatky MA, Boothroyd DB, Bravata DM, et al. Coronary artery bypass surgery compared with percutaneous coronary interventions for multivessel disease: a collaborative analysis of individual patient data from ten randomised trials. Lancet. Apr. 4. 2009;373(9670):1190-7. [pmid: 19303634].
8 Wilt TJ, Brawer MK, Jones KM, et al. Radical prostatectomy versus observation for localized prostate cancer. N Engl J Med. Jul. 19. 2012;367(3):203-13. [pmid: 22808955].