# Methods

This project assesses the predictive validity of signals for updating made in 2009 for CERs that have since been updated. We start with a description of the original process to detect signals, and then describe how we assessed their validity.

## Original Process in 2009 Report

### Identifying New Evidence From Published Studies

#### Search Strategy

We started by using the search strategy employed in the original report. We conducted a limited literature search that included at least Medline/PubMed and/or Cochrane, and, on a topic specific basis, additional databases. The search included five general medical interest journals (Annals of Internal Medicine, British Medical Journal, Journal of the American Medical Association, Lancet, and the New England Journal of Medicine) and the specialty journals most relevant to that topic. The specialty journals were those most highly represented among the references from the original report. In general, we followed the search strategy from the original CER. However, we did make some modifications. For example, if we were aware of new drugs for the condition, their names were added to the search terms. Search inception dates were 6 to 12 months prior to the end date of the original CER search, in order to ensure overlap between the searches.

#### Study Selection and Abstraction

In general, we also used the same inclusion and exclusion criteria as the original CER. A single reviewer, experienced in systematic reviews, conducted a screening of the titles and abstracts and requested any articles deemed relevant to the topic. From those articles, a single reviewer extracted relevant data from articles that met the inclusion criteria and constructed an evidence table. These data included any study level details extracted in the original CER, e.g., sample size, study design, and outcomes measured, as well as the outcomes themselves.

### Identifying New Evidence From Experts and Expert Opinion

For each topic, a questionnaire matrix that listed the key questions and conclusions from the original executive summary was created. The matrix was sent to experts in the field, including the original project leader, technical expert panel members, and peer reviewers. These experts were asked to complete the matrix, indicating whether each listed conclusion was, to their knowledge, still valid, and if not, to provide information about new evidence.

Once abstraction of the study conditions and findings for each new included study was completed and expert opinions were received, we assessed whether the new findings provided a signal for the need to update, on a conclusion-by-conclusion basis. Table 1 lists the criteria used for reaching conclusions.6

Table 1 RAND method

RAND's Label | RAND Method Indications for the Need for an Update
Still valid | Original conclusion is still valid and this portion of the original report does not need updating. This conclusion was reached if we found no new evidence or only confirmatory evidence and all responding experts assessed the CER conclusion as still valid, we classified the CER conclusion as still valid.
Possibly out of date | Original conclusion is possibly out of date and this portion of the original report may need updating. This conclusion was reached if we found some new evidence that might change the CER conclusion, and /or a minority of responding experts assessed the CER conclusion as having new evidence that might change the conclusion, then we classified the CER conclusion as possibly out of date.
Probably out of date | Original conclusion is probably out of date and this portion of the original report may need updating. This conclusion was reached if we found substantial new evidence that might change the CER conclusion, and/or a majority of responding experts assessed the CER conclusion as having new evidence that might change the conclusion, then we classified the CER conclusion as probably out of date.
Out of date | Original conclusion is out of date. This conclusion was reached if we found new evidence that rendered the CER conclusion out of date or no longer applicable, we classified the CER conclusion as out of date. Recognizing that our literature searches were limited, we reserved this category only for situations where a limited search would produce prima facie evidence that a conclusion was out of date, such as the withdrawal of a drug or surgical device from the market, a black box warning from FDA, etc.

CER = comparative effectiveness review; FDA = U.S. Food and Drug Administration

For each CER, we constructed a summary table that included the following for each key question: original conclusion(s), findings of the new literature search, summary of expert assessment, and our final assessment of the currency of the conclusion(s).

### Determining Priority for Updating a CER

For each report, we provided an assessment as to whether each conclusion was up to date. We then needed to assign an overall judgment of the priority for updating. We used two criteria in making our final conclusion for a CER:

- How much of the CER is possibly, probably, or certainly out of date?
- How out of date is that portion of the CER? For example, would the potential changes to the conclusions involve refinement of original estimates or do the potential changes include the finding that some therapies are no longer favored or may no longer be in use? Is the portion of the CER that is probably or certainly out of date an issue of safety (a drug withdrawn from the market, a black box warning) or the availability of a new drug within class (the latter being less of a signal to update than the former)?

This final conclusion was a global judgment made by all the individuals working on each particular CER. We classified CERs as being low, medium, or high priority for updating, with a notation explaining the rationale for high priority updates.

## Assessment of Predictive Validity

Our 2009 report assessed 11 CERs and classified 4 as a high priority for updating, 4 as a medium priority for updating and 3 as a low priority for updating (see Table 2). One of the low-priority topics, “Comparative Effectiveness of Percutaneous Coronary Interventions and Coronary Artery Bypass Grafting for Coronary Artery Disease,” was considered low priority for an update because AHRQ had already commissioned an Individual Patient Data meta-analysis, which was considered to be an “update” of the CER, and which has since been published in 2009.^7^

Table 2 Comparative effectiveness reviews assessed

CER | 2009 Prediction | Update Commissioned by AHRQ
Comparative Effectiveness of Management Strategies for Gastroesophageal Reflux Disease | High | Yes
Effectiveness of Noninvasive Diagnostic Tests for Breast Abnormalities | High | Yes
Comparative Effectiveness of Epoetin and Darbepoetin for Managing Anemia in Patients Undergoing Cancer Treatment | High | Yes
Comparative Effectiveness and Safety of Analgesics for Osteoarthritis | High | Yes
Efficacy and Comparative Effectiveness of Off-Label Use of Atypical Antipsychotic | Medium | Yes
Comparative Effectiveness of Drug Therapy for Rheumatoid Arthritis and Psoriatic Arthritis in Adults | Medium | Yes
Comparative Effectiveness of Treatments To Prevent Fractures in Men and Women With Low Bone Density or Osteoporosis | Medium | Yes
Comparative Effectiveness of Second-Generation Antidepressants in the Pharmacologic Treatment of Adult Depression | Low | Yes
Comparative Effectiveness of Angiotensin-Converting Enzyme Inhibitors (ACEIs) and Angiotensin II Receptor Antagonists (ARBs) for Treating Essential Hypertension | Low | Yes
Comparative Effectiveness of Therapies for Clinically Localized Prostate Cancer | Medium | No
Comparative Effectiveness of Percutaneous Coronary Interventions and Coronary Artery Bypass Grafting for Coronary Artery Disease | Low | No

For the remaining CERs, AHRQ elected to support full updates of all of them, except the report on clinically localized prostate cancer, for which it was felt to be prudent to wait for the upcoming results of the Prostate Cancer Intervention Versus Observation Trial (PIVOT).8 This presented us with a natural experiment in which all reports, regardless of update priority status, were going to get the gold standard of a complete update. This gave us the opportunity to assess for both false positives (reports classified as high priority, but which when updated had no major change in conclusions) and false negatives (reports classified as low priority, but which when updated had major changes in conclusions) in terms of the 2009 predictions. In order to do so, we took the conclusions from the original CER and then tried to match it with the closest similar conclusion from the update. We then assessed the degree of concordance between the 2009 prediction and the updated conclusion. We used the following criteria:

Good:

- If original prediction was “still valid” and there was no new relevant evidence or if new evidence continued to support the conclusion.
- If original prediction was “possibly out of date,” “probably out of date,” or “out of date” and new evidence was added that changed the conclusions by a substantial amount.

Fair:

- If original prediction was “still valid” and new evidence supported changes in some but not other aspects of the conclusions.
- If original prediction was “possibly out of date” but new evidence was not incorporated into the updated conclusions and there was no substantive change in conclusion.
- If original prediction was “probably out of date” or “out of date” and there were changes to conclusions on some but not other points.

Poor:

- If original prediction was “still valid” and there was new evidence that substantially changed the conclusions.
- If original prediction was “probably out of date” or “out of date” and new evidence ended up not being incorporated into the update and no substantive change in conclusion.

Examples are as follows:

Example 1:

- Original conclusion (from CER on analgesics for osteoarthritis):
  There are no clear differences between various nonaspirin, nonselective NSAIDS or partially selective NSAIDS in efficacy for pain relief or improvement.
- 2009 surveillance assessment:
  Conclusion is still valid.
- Conclusion from 2011 CER update:
  No clear difference in efficacy for pain relief, or withdrawals due to lack of efficacy.
- Concordance: good

Example 2:

- Original conclusion (from CER on analgesics for osteoarthritis):
  Etoricoxib is associated with fewer GI adverse events than nonselective NSAIDS.
- 2009 surveillance assessment:
  Possibly out of date.
- Conclusion from 2011 CER update:
  No comparable conclusion, as etoricoxib was not included as it did not gain FDA approval for sale in the United States.
- Concordance: good

Example 3:

- Original conclusion (from CER on second-generation antidepressants)
  Overall discontinuation rates did not differ significantly between SSRIs as a class and bupropion, mirtazapine, nefazodone, trazodone, and venlafaxine. In the case of venlafaxine compared with SSRIs, higher discontinuation rates because of adverse events appear to be balanced by lower discontinuation rates because of lack of efficacy.
- 2009 surveillance assessment:
  Conclusion is possibly out of date and this portion may need updating based on new analysis showing lower dropout rate with escitalopram.
- Conclusion from 2011 CER update:
  Meta-analyses of numerous efficacy trials indicate that overall discontinuation rates are similar. Duloxetine and venlafaxine have a higher rate of discontinuations because of adverse events than SSRIs as a class. Venlafaxine has a lower rate of discontinuations because of lack of efficacy than SSRIs as a class.
- Concordance: Fair. The escitalopram data did not end up in the conclusions.

Example 4:

- Original conclusion from CER on second generation antidepressants)
  Three head-to-head RCTs suggest that no substantial differences exist between fluoxetine and sertraline, fluvoxamine and sertraline, and trazodone and venlafaxine, regarding relapse. Twenty-one placebo-controlled trials support the general efficacy and effectiveness of most second-generation antidepressants for preventing relapse or recurrence. No evidence exists for duloxetine.
- 2009 surveillance assessment:
  Conclusion is possibly out of date and this portion of the CER may need updating to include evidence for duloxetine.
- Conclusion from 2011 CER update:
  Based on results from six efficacy trials and one naturalistic study, no significant differences exist between escitalopram and desvenlafaxine, escitalopram and paroxetine, fluoxetine and sertraline, fluoxetine and venlafaxine, fluvoxamine and sertraline, and trazodone and venlafaxine for preventing relapse or recurrence.
- Concordance: Fair. No duloxetine evidence ended up being included in this key question.

Example 5:

- Original conclusion (from CER on management of GERD)
  Medical therapy with PPIs and surgery (fundoplication) appeared to be similarly effective for improving symptoms and decreasing esophageal acid exposure.
- 2009 surveillance assessment:
  Conclusion is still valid and this portion of the CER does not need updating.
- Conclusion from 2011 CER update:
  The 2005 CER concluded that medical therapy with PPIs and antireflux surgery were similarly effective in improving GERD-related symptoms and decreasing esophageal acid exposure, although some surgical patients required ongoing medical therapy post procedure. With the addition of long-term followup data (7 to 12 years) from two previously reviewed studies and results from two new RCTs, our updated review found that patients who underwent antireflux surgery experienced a greater improvement in heartburn and regurgitation at followup than patients who received medical treatment alone.
- Concordance: Poor—update indicates symptoms are better with surgery.

We assessed “concordance” rather than “agreement” since the matching of original conclusion to updated conclusion was often challenging, and “agreement” implies a more direct comparison of original-to-updated-conclusion than always was present. For this reason we did not make comparisons using a 2×2 table.

We then made a summary assessment of the CER's priority for updating, based on the updated conclusions. We used the same criteria as in the prospective assessment:

- How much of the report was out of date.
- How out of date it was.

We compared the agreement between the original assessment of priority and the actual changes using the kappa statistic.

For concordance of assessments of individual conclusions, an additional complicating factor was the time delay between the limited literature search to assess for signals (2009) and the search date of the update report (2010–2012). Therefore, for conclusions with poor concordance, we reviewed whether it may have been influenced by new evidence published after the surveillance signals search.