# Introduction

The Medicare Prescription Drug, Improvement, and Modernization Act (MMA) of 2003 mandated the Department of Health and Human Services' Center for Medicare and Medicaid Services to develop a prescription drug benefit for elderly Medicare beneficiaries (Part D) and to implement a number of other improvements to Medicare benefits. Section 1013 of the MMA authorized the Agency for Healthcare Research and Quality (AHRQ) to develop a program to conduct research on the comparative clinical effectiveness of medications, devices, and other interventions in order to support informed health care decision making by patients, clinicians, and policymakers. (http://effectivehealthcare.ahrq.gov/)

Thus, the Effective Health Care (EHC) program, established in 2005, follows three basic approaches to research: The program synthesizes the current scientific evidence, generates new scientific evidence, and translates research findings into concise materials written in plain language for a consumer audience. Under this program, the AHRQ-funded Evidence-based Practice Centers (EPCs) throughout the United States and Canada have been responsible for synthesizing the evidence and developing research reviews, including comparative effectiveness reviews (CERs).

Like all evidence reviews, the CERs have a number of objectives. First, they assess the relative benefits and harms of a variety of treatments and other interventions. They are intended to help consumers, health care providers, and others in making informed choices among treatment alternatives by examining effectiveness across a broad spectrum of consumers and identifying adverse events of concern. Finally, CERs identify gaps in existing scientific evidence and suggest new research.

In early 2008, AHRQ determined that in order to meet their intended objectives the EHC Program should assess the need for the findings of the CERs completed to that point to be updated. The Southern California Evidence-based Practice Center (SCEPC) was tasked with conducting this assessment.

The science of determining when systematic reviews need updating has been developing for the past decade. Prior to 2001, no method or criteria existed to determine whether evidence-based products remained valid or whether the evidence underlying them had been superseded by newer work. Since then there have been studies done by the SCEPC1-3 and by Shojania and colleagues4 and the Drug Effectiveness Review Project5 about the methods to determine signals for updating reviews. The method used by us in 2009 was based on our prior work in 2001 and involved limited literature searches and expert opinion. It produces assessments of each conclusion in a CER, as well as a summary assessment of a CER's priority for updating. In 2009, we produced a report to AHRQ that described the process for detecting signals and the results of an assessment of 11 CERs produced to that point in time.6 This method is now one basis for the EPC Surveillance Program. It has proven feasible to conduct periodic surveillance on a large portfolio of CERs.3 However, while the method has face validity, an explicit test of predictive validity has not been performed. We took advantage of a natural experiment to assess the validity of the surveillance signals method.