# Conclusions, Limitations, and Discussion

This assessment of the predictive validity of a method to assess a CER for signals for updating yielded generally favorable results. The vast majority of individual conclusions were judged to have good concordance between the 2009 prediction and the subsequent updated conclusion. The one instance of poor concordance also had new evidence published after the surveillance signals had been assessed, and nevertheless occurred in a CER already judged as being high priority for updating.

There are three primary limitations of this study. The first is sample size. We were able to assess only nine CERs. However, this included CERs assessed as high, medium, and low priority, thus allowing us to assess the possibility of “false negatives” (CERs assessed as low priority for updating which nevertheless got a full update). It is unlikely ever again to be the situation where low-priority CERs get subjected to the gold standard of a full update. Our findings that neither CER judged as low priority had any substantive changes in conclusions will reinforce the decision to put scarce resources into other topics rather than commission updates of low-priority CERs.

A second limitation is the matching of original conclusions to updated conclusions. In some updated reports the authors did this for us. But in most cases this was not done, and in some circumstances it was challenging determining the appropriate “match” for the original conclusion. Our Appendix table lists each original conclusion and matching updated conclusion so that readers may judge this for themselves. Considering that some target audiences want to know “What's new?” 3 improving this identification should be a priority for updated reports.

The third principal limitation of this study is that the 2013 assessment could not be made “blind” to the 2009 predictions. Our EPC did both assessments, and even had some other group done the 2013 assessment we could not have enforced “blinding” since the 2009 assessments are in the public domain. We tried to guard against bias by having explicit reasons for each judgment, and presenting these for readers to examine and either agree or disagree with them. Our reasoning should be transparent.

With the limitation of small sample size kept in mind, we offer same preliminary conclusions about the surveillance signal method:

1. Low-priority CERs are unlikely to have any substantive changes in conclusions.
2. Conclusions judged likely to be “still valid” almost certainly are still valid.
3. Conclusions judged to be “out of date” almost certainly are out of date.
4. Safety concerns and the appearance of new class, more efficacious therapies are the best targets for high-priority updates.
5. The classification of individual conclusions as “possibly” or “probably” out of date due to new evidence may be slightly too sensitive as a signal; there were a number of such instances where the update report conclusion did not change because the new evidence identified in the signal search was either rejected or insufficient to change the conclusion.

In sum, this assessment provides some support for the predictive validity of this method of assessing CERs for signals of the need for updating. Future research is likely going to be confined to assessing updates of CERs judged to be medium or high priority for updating. Future assessment of the factors leading to changes in individual conclusions may help refine the criteria for distinguishing between high and medium priority update topics. However, extra time and effort at distinguishing “possibly” from “probably” out of date conclusions or in further refining the global assessment of medium from high priority update topics may begin to make the surveillance process resemble the actual update, which is not the goal of surveillance. In this application, the surveillance process worked very well, close to near perfectly (a kappa of 0.8 and above is considered “near perfect” agreement). No low-priority CER was judged as having had a substantive change to conclusion in the update, while 3 of 4 high priority CERs did have substantive changes to the conclusions. The results suggest that it is very unlikely that there is practice-changing new evidence concerning a systematic review judged as low priority for updating, and supports a policy of not further assessing systematic reviews for possible updating until new evidence is sufficient to warrant at least a medium priority.