# Conclusion Assessments Across All Nine Comparative Effectiveness Reviews

Table A-1 Comparative effectiveness of management strategies for gastoesophageal reflux disease (GERD)

Table A-2 Effectiveness of noninvasive diagnostic tests for breast abnormalities

Table A-3 Comparative effectiveness and safety of analgesics for osteoarthritis

Table A-4 Efficacy and comparative effectiveness of off-label use of atypical antipsychotics

Table A-5 Comparative effectiveness of second-generation antidepressants in the pharmacologic treatment of adult depression

Table A-6 Comparative effectiveness of angiotensin-converting enzyme inhibitors (aceis) and angiotensin ii receptor antagonists (arbs) for treating essential hypertension

Table A-7 Comparative effectiveness of drug therapy for rheumatoid arthritis and psoriatic arthritis in adults

Table A-8 Comparative effectiveness of treatments to prevent fractures in men and women with low bone density or osteoporosis

Table A-9 Comparative effectiveness of epoetin and darbepoetin for managing anemia in patients undergoing cancer treatment