# References

1 Higgins J, Green S, editors. Cochrane Handbook for Systematic Reviews of Interventions Version 5.0.2. The Cochrane Collaboration. 2009.
2 Shojania KG, Sampson M, Ansari MT, et al. How quickly do systematic reviews go out of date? A survival analysis. Ann Intern Med. Aug. 21. 2007;147(4):224-33. [pmid: 17638714].
3 Garritty C, Tsertsvadze A, Tricco AC, et al. Updating systematic reviews: an international survey. PloS one. 2010;5(4):e9914. [pmid: 20376338].
4 Moher D, Tsertsvadze A, Tricco AC, et al. When and how to update systematic reviews. Cochrane database of systematic reviews. 2008;(1):MR000023. [pmid: 18254126].
5 Jadad AR, Cook DJ, Jones A, et al. Methodology and reports of systematic reviews and meta-analyses: a comparison of Cochrane reviews with articles published in paper-based journals. JAMA. Jul. 15. 1998;280(3):278-80. [pmid: 9676681].
6 Moher D, Tetzlaff J, Tricco AC, et al. Epidemiology and reporting characteristics of systematic reviews. PLoS Med. Mar. 27. 2007;4(3):e78. [pmid: 17388659].
7 MacLean C, Alexander A, Carter J, et al. Comparative Effectiveness of Treatments To Prevent Fractures in Men and Women With Low Bone Density or Osteoporosis. Comparative Effectiveness Review. Rockville, MD. 2007. www.effectivehealthcare.ahrq.gov/reports/final.cfm.
8 MacLean C, Newberry S, Maglione M, et al. Systematic review: comparative effectiveness of treatments to prevent fractures in men and women with low bone density or osteoporosis. Ann Intern Med. Feb. 5. 2008;148(3):197-213. [pmid: 18087050].
9 Shekelle P, Maglione M, Bagley S, et al. Efficacy and Comparative Effectiveness of Off-Label Use of Atypical Antipsychotics, Efficacy and Comparative Effectiveness of Off-Label Use of Atypical Antipsychotics. Rockville (MD). 2007.
10 Maher AR, Maglione M, Bagley S, et al. Efficacy and comparative effectiveness of atypical antipsychotic medications for off-label uses in adults: a systematic review and meta-analysis. JAMA. Sep. 28. 2011;306(12):1359-69. [pmid: 21954480].
11 Shekelle P, Takata G, Newberry S, et al. Management of Acute Otitis Media: Update. Rockville, MD. Agency for Healthcare Research and Quality. 2010.
12 Sampson M, Shojania KG, Garritty C, et al. Systematic reviews can be produced and published faster. J Clin Epidemiol. Jun. 2008;61(6):531-6. [pmid: 18471656].
13 Sampson M, Shojania KG, McGowan J, et al. Surveillance search techniques identified the need to update systematic reviews. J Clin Epidemiol. Aug. 2008;61(8):755-62. [pmid: 18586179].
14 Cohen AM, Hersh WR, Peterson K, et al. Reducing workload in systematic review preparation using automated citation classification. J Am Med Inform Assoc. Mar–Apr;. 2006;13(2):206-19. [pmid: 16357352].
15 Wallace BC, Small K, Brodley CE, et al. Active learning for biomedical citation screening. Proceedings of the 16th ACM SIGKDD international conference on Knowledge discovery and data mining. 2011. Washington DC, USA. ACM.
16 Aphinyanaphongs Y, Tsamardinos I, Statnikov A, et al. Text categorization models for high-quality article retrieval in internal medicine. Journal of the American Medical Informatics Association : JAMIA. Mar–Apr. 2005;12(2):207-16. [pmid: 15561789].
17 Cohen AM, Ambert K, McDonagh M. Cross-topic learning for work prioritization in systematic review creation and update. J Am Med Inform Assoc. Sep–Oct. 2009;16(5):690-704. [pmid: 19567792].
18 Cohen AM, Hersh WR. A survey of current work in biomedical text mining. Brief Bioinform. January. 1. 2005. 2005;6(1):57-71. [pmid: 15826357].
19 Kilicoglu H, Demner-Fushman D, Rindflesch TC, et al. Towards automatic recognition of scientifically rigorous clinical research evidence. Journal of the American Medical Informatics Association : JAMIA. Jan–Feb. 2009;16(1):25-31. [pmid: 18952929].
20 Wallace BC, Trikalinos TA, Lau J, et al. Semi-automated screening of biomedical citations for systematic reviews. BMC Bioinformatics. 2010;11:55. [pmid: 20102628].
21 Cohen AM, Ambert K, McDonagh M. A Prospective Evaluation of an Automated Classification System to Support Evidence-based Medicine and Systematic Review. AMIA ... Annual Symposium proceedings / AMIA Symposium. AMIA Symposium. 2010;2010:121-5. [pmid: 21346953].
22 Cohen AM. Performance of support-vector-machine-based classification on 15 systematic review topics evaluated with the WSS@95 measure. Journal of the American Medical Informatics Association : JAMIA. Jan–Feb. 2011;18(1):104. author reply -5. [pmid: 21169622].
23 Hastie T, Tibshirani R, Friedman J. The Elements of Statistical Learning: Data Mining, Inference, and Prediction. New York. Springer Verlag. 2009.
24 Genkin A, Lewis D, Madigan D. Large-scale bayesian logistic regression for text categorization. Technometrics. 2007;49:291-304.
25 Tibshirani R. Regression Shrinkage and Selection by Lasso. Journal of the Royal Statistical Society, Series B. 1996;58:267-88.
26 Shetty KD, Dalal SR. Using information mining of the medical literature to improve drug safety. Journal of the American Medical Informatics Association : JAMIA. 2011. Jun. 2. [pmid: 21546507].
27 Widmer G, Kubat M. Learning in the Presence of Concept Drift and Hidden Contexts. Machine Learning. 1996;23(1):69-101.
28 Tsymbal A, Pechenizkiy M, Cunningham P, et al. Dynamic integration of classifiers for handling concept drift. Information Fusion. 2008;9(1):56-68.
29 Blitzer J, McDonald R, Pereira F. Domain adaptation with structural correspondence learning. Proceedings of the 2006 Conference on Empirical Methods in Natural Language Processing. 2006. Sydney, Australia. Association for Computational Linguistics. 120-8.
30 Pan SJ, Yang Q. A Survey on Transfer Learning. 2010;22(10):15.
31 Frustratingly Easy Domain Adaptation. Proceedings of the 45th Annual Meeting of the Association of Computational Linguistics. 2007. Prague, Czech Republic. Association for Computational Linguistics.
32 Cock PJ, Antao T, Chang JT, et al. Biopython: freely available Python tools for computational molecular biology and bioinformatics. Bioinformatics. Jun. 1. 2009;25(11):1422-3. [pmid: 19304878].
33 Saag KG, Zanchetta JR, Devogelaer JP, et al. Effects of teriparatide versus alendronate for treating glucocorticoid-induced osteoporosis: thirty-six-month results of a randomized, double-blind, controlled trial. Arthritis and rheumatism. Nov. 2009;60(11):3346-55. [pmid: 19877063].
34 US National Library of Medicine. MeSH Browser. U.S. National Institutes of Health. 2010.
35 Freund Y, Schapire R. Experiments with a new boosting algorithm. Machine Learning: Proceedings of the Thirteenth International Conference. San Francisco. Morgan Kaufman. 1996:148-56.
36 Friedman JH. Greedy function approximation: A gradient boosting machine. Annals of Statistics. 2001;29(5):1189-232.
37 Friedman J, Hastie T, Tibshirani R. Regularization Paths for Generalized Linear Models via Coordinate Descent. Journal of statistical software. 2010;33(1):1-22. [pmid: 20808728].
38 Deerwester S, Dumais S, Furnas G, et al. Indexing by Latent Samentic Analysis. Journal of the American Society for Information Science. 1990;41:391-407.
39 Deerwester S, Dumais S, Landauer T, et al. Improving information-retrieval with latent semantic indexing. Proceedings of the AS1S annual meeting. 1988;25:36-40.
40 DeLong ER, DeLong DM, Clarke-Pearson DL. Comparing the areas under two or more correlated receiver operating characteristic curves: a nonparametric approach. Biometrics. Sep. 1988;44(3):837-45. [pmid: 3203132].
41 Efron B, Tibshirani R. Bootstrap Methods for Standard Errors, Confidence Intervals, and Other Measures of Statistical Accuracy. Statistical Science. 1986;1(1):54-75.
42 Tsuang J, Marder SR, Han A, et al. Olanzapine treatment for patients with schizophrenia and cocaine abuse. The Journal of clinical psychiatry. Dec. 2002;63(12):1180-1. [pmid: 12530415].
43 Hamilton JD, Nguyen QX, Gerber RM, et al. Olanzapine in cocaine dependence: a double-blind, placebo-controlled trial. The American journal on addictions / American Academy of Psychiatrists in Alcoholism and Addictions. Jan–Feb. 2009;18(1):48-52. [pmid: 19219665].
44 Sato Y, Manabe S, Kuno H, et al. Amelioration of osteopenia and hypovitaminosis D by 1alpha-hydroxyvitamin D3 in elderly patients with Parkinson’s disease. Journal of neurology, neurosurgery, and psychiatry. Jan. 1999;66(1):64-8. [pmid: 9886454].
45 Ebeling PR, Wark JD, Yeung S, et al. Effects of calcitriol or calcium on bone mineral density, bone turnover, and fractures in men with primary osteoporosis: a two-year randomized, double blind, double placebo study. The Journal of clinical endocrinology and metabolism. Sep. 2001;86(9):4098-103. [pmid: 11549632].
46 Glanville JM, Lefebvre C, Miles JN, et al. How to identify randomized controlled trials in MEDLINE: ten years on. J Med Libr Assoc. Apr. 2006;94(2):130-6. [pmid: 16636704].