# Methods

## Data Sources

We obtained PubMed citations retrieved by the SCEPC (until January 2011) for its review of the comparative effectiveness of interventions in preventing fractures in persons with osteoporosis (LBD) and its review of the efficacy and comparative effectiveness of off-label uses of atypical antipsychotics (AAP). MEDLINE citations were retrieved in plain text format and parsed using Python 2.7.2 (Python Software Foundation, http://python.org); specifically, we used the Biopython 1.52 package within Python to retrieve full MEDLINE citations from Entrez PubMed databases.32 We did not evaluate PubMed citations that had not yet been assigned MEDLINE indexing information (such as MeSH and Publication Type terms). We also excluded articles obtained exclusively from non-PubMed databases (such as PsycInfo and EMBASE). Excluding non-PubMed databases is a limitation whose importance varied by study. For the LBD update, all relevant studies were found in PubMed. For the AAP update, 31 articles included in the final report were not located in PubMed. Of those, 14 were scientific information packets (which will always require human review), 9 were identified by mining references of included reports, and 8 were found in poster presentations.

The search strategies and primary selection criteria for LBD have been discussed extensively in other reports.7–9 Briefly, in the LBD study, the interventions consisted of multiple drugs (including bisphosphonate drugs, calcitonin, selective estrogen receptor modulators, parathyroid hormone derivatives, and menopausal hormone therapy) and exercise therapy. The primary outcomes of interest were fractures and AEs but the search strategy also attempted to capture articles discussing predisposing conditions by searching for terms such as osteoporosis, osteopenia, and bone mineral density, as well as fractures. The search was limited to English language articles, but no limits were placed on publication type. The initial search (1966–2006) yielded 14,700 articles with full MEDLINE citations, and the updated search (containing a slightly different set of interventions) retrieved 7,051 articles with full MEDLINE citations (spanning 2006–2010). We did not analyze 219 PubMed articles from the LBD updated search that were not indexed in MEDLINE, as our algorithms currently require MEDLINE indexing information.

The search strategies and selection criteria for AAP have also been discussed in other reports.9 In the original AAP review, the interventions consisted of atypical antipsychotic drugs, including olanzapine, risperidone, quetiapine, and clozapine. Outcomes of interest included dementia, obsessive-compulsive disorder, and post-traumatic stress disorder, and outcomes could be excluded if re-classified by the U.S. Food and Drug Administration (FDA) as an approved indication. The search conducted in 2006 yielded 1,307 MEDLINE citations requiring human classification. The updated search added outcomes such as anorexia nervosa, bulimia, and substance abuse to the list of off-label uses under consideration; 3,591 MEDLINE citations were retrieved. We did not analyze 19 PubMed articles from the AAP original search and 142 PubMed articles from the updated search that were not indexed in MEDLINE. For both studies, articles retrieved for update and original searches were mutually exclusive.

During the initial modeling phase, we had access to researcher decisions on the original search results. The LBD training document literature consisted of 14,700 retrieved articles, of which 382 articles would have passed the second stage filter: 218 for efficacy/effectiveness and 279 articles for AEs. The LBD update body of literature consisted of 7,051 retrieved articles (of which 127 would have passed the second stage filter: 63 for efficacy/effectiveness and 92 for AEs). The AAP training literature consisted of 1,307 retrieved articles, of which 98 articles would have passed the second stage filter: 82 for efficacy/effectiveness and 91 for AEs. The AAP update consisted of 3,591 retrieved articles, of which 116 would have passed the second stage filter: 101 for efficacy/effectiveness and 105 for AEs. Of note, articles were excluded at the second stage for critical reasons (e.g., inappropriate study design, no mention of fractures, inappropriate intervention, outcome was an on-label indication, etc.) and reasons of timing (duplicate data, inclusion in prior meta-analysis). We considered the latter articles to have passed a second stage of review because they were not excluded for intrinsic problems in study design or target population. We blinded the statistical learning model to researcher decisions involving the updated search results; as such, we could effectively simulate a true update in which the update search results would not have been known.

We did not have access to completely accurate determinations of first-stage filtering outcomes; as a result we did not include this outcome in any model. In addition, while we did not model first-stage outcomes due to data limitations, we also believed that such articles were not important to the final results; indeed, reducing this number was also a researcher goal as all articles passing the first stage required a time-consuming full-text review.

## Processing MEDLINE Citations

Each fully indexed MEDLINE citation contains several (usually 10–15) indexing terms; each term is often modified by one or more subheadings. As described above, we aimed to construct a limited set of important variables using key MeSH indexing terms and associated subheadings that are tied to the interventions and outcomes of interest. Figure 1 shows how a data was extracted from one citation using terms adapted from the 2006 LBD search strategy.7,33 Of note, data related to generic study characteristics (such as RCT or human study) were extracted from all studies. The key MeSH terms were found using the extent search strategies. One author divided each search strategy into terms related to interventions and terms related to outcomes. This task was made easier by the fact that outcome and intervention terms were usually grouped within each search. For example, one search in the original LBD review was “(osteoporosis or osteopenia or osteopaenia or fracture* or bone mineral OR fractures [mh] OR bone density) AND (raloxifene* OR evista OR tamoxifen* OR nolvadex OR emblon OR fentamox OR soltamox OR tamofen)”.7 Hence, we could identify interventions (raloxifene, etc.) and outcomes (osteoporosis, osteopenia, etc.) without substantial effort. (Clearly, we will need to expend more effort on poorly defined search strategies.) At that point the MeSH database was programmatically queried to retrieve potential matches (obtained by via direct term and synonym matching) that were reviewed by one of the authors. Several erroneous terms were excluded at this stage. For example, “exercise test”—a diagnostic test—was retrieved when searching for exercise but manually excluded because only therapeutic exercise therapy was relevant to this review. Because this process relies heavily on the original search strategies, it does not use substantially more expertise than what went into the original report.34

Figure 1 MEDLINE citation processing example

MH = MEDLINE indexing term; PMID = PubMed identifier; PT = publication type; RCT = randomized controlled trial; TI = title

Figure 1 is a schematic diagram that shows how data was extracted from one example citation using terms adapted from a stylized version of 2006 LBD review search strategy. In the first stage, key terms in the search strategy are retrieved, including those related to the outcome (“Osteoporosis OR osteopenia OR fractures OR bone density”) and intervention (“alendronate or Fosamax”). Also in the first stage, other key terms (not necessarily in the search strategy) are extracted with respect to study design, demographic groups, subjects, and others. In this example, two fields are of interest (“randomized controlled trial” and “humans”). Citations are the parsed in such a fashion as to indicate whether key terms are present. In this example (“Effects of teriparatide versus alendronate for treating glucocorticoid-induced osteoporosis: thirty-six-month results of a randomized, double-blind, controlled trial”; http://www.ncbi.nlm.nih.gov/pubmed/19877063), the following key facts were identified: Alendronate tagged with therapeutic use; Osteoporosis tagged as being treated (and is also a complication); Human study mentioned; and RCT mentioned. These facts form the basis of the positive explanatory variables used when modeling relevance for this citation.

We then created a set of 46 binary explanatory variables based on whether the exact intervention or outcome terms were present in the MEDLINE citation and linked to particular subheadings. We further created a set of 46 matching explanatory variables based on whether other interventions or outcomes (that are not the outcomes and interventions of interest) were present in the MEDLINE citation and linked to particular subheadings. For example, if the only outcome of interest in a particular article is “fractures,” if “fractures” are indexed in the citation in association with “drug therapy”, we set the variable “outcome_drug_therapy” equal to one. However, if in the same article, “rheumatic diseases” is also indexed in conjunction with “drug therapy”, we would set a variable “other_outcome_drug_therapy” equal to 1 as well. The latter might indicate that other diseases were of primary importance in the article. We used a similar process for interventions.

In addition, we created a set of 29 binary explanatory variables related to broader characteristics from MeSH indexing terms and publication type terms-- including demographic group (gender and age), treatment target (human, animal, in vitro study, and others), and publication type (review, clinical trial, meta-analysis, and others). Finally we created variables indicating whether any intervention or outcome (or synonym of either) was explicitly mentioned in the title or in the article’s MeSH index, whether the article was particularly short (1 or 2 pages in length), and whether “randomized controlled trial” or “meta-analysis” was mentioned in the title or abstract. Our approach is parsimonious in that we used only these 121 variables, instead of the full text approach that would have to deal with potentially thousands of explanatory variables and consequently would have the potential for overfitting, resulting in possible loss of out-of-sample predictive power. Although we relied on expert knowledge to some extent while extracting such data, we relied on statistical algorithms to select the most important features (see below).

## Statistical Classification

We created a series of eight models based on all combinations of: two outcomes (inclusion in the final report for either efficacy or AEs); training data with associated explanatory variables from two reviews (AAP and LBD); and, two statistical learning algorithms (GBM and GLMnet). After deriving each model empirically using training data from original review, we generated predictions for articles in each corresponding update. All statistical modeling was conducted in R 2.10 (R Foundation, www.r-project.org/). We also used these base models to create combination analyses. We tested a “hybrid” approach that used the maximum prediction probability of relevance from both approaches (GBM- or GLMnet-based). We also evaluated how well GBM and GLMnet could predict inclusion for any outcome (efficacy/effectiveness or AEs) in a given review update (AAP or LBD). We modeled relevance as a function of the explanatory variables discussed above while solely using those articles retrieved in the original search (1966–2005/6 literature–the training data). To simulate a true update in which the update search results would not have been known, we blinded the statistical learning model to researcher decisions from study updates. Each step is explained in detail below.

We constructed separate models for predicting inclusion in efficacy/effectiveness or AE analyses because article characteristics predictive of relevance were likely to be quite different between the two analyses. For both, we aimed to retain the maximum number of relevant citations (true positives), while minimizing the number of irrelevant citations detected (false positives). We also evaluated our models’ performance in predicting inclusion in either analysis. The latter analysis is most relevant to current AHRQ practice, as both efficacy/effectiveness and AE analyses are required for comparative effectiveness reviews. However, we showed disaggregated results as well because other researchers may be interested in one type of study.

We determined each model specification (efficacy/effectiveness and AE analyses for both LBD and AAP) using several statistical methods. The first method we considered was gradient-boosting machine (GBM), a non-parametric tree based prediction approach based on boosting.35,36 In the general boosting framework, models are built in a stage-wise fashion, with weak (i.e. moderately inaccurate) classifiers combined to create a strong final classifier. GBM is a specific implementation of boosting and consists of a general, automated, data-adaptive modeling algorithm that can estimate the nonlinear relationship between a variable of interest and a large number of covariates using a sequence of simple classifiers combined in an optimal way. The algorithm generates a large sequence of simple classification trees. Each tree is fit to the prediction residuals for the preceding tree (i.e. the deviations between the observed and predicted values). (See Figure 2 for an example tree).

Figure 2 Example GBM tree

GBM = gradient boosting machine

Figure 2 shows a hypothetical decision tree used in the gradient boosting machine (GBM) statistical model. The tree includes 3 sequential decision points that must be satisfied for the article to be classified as relevant. Each node uses article characteristics that were described in the text. The first node requires that the article be an RCT; articles classified as relevant in the first node are then evaluated at the second node, which requires that the agent (drug or other therapy) be tagged with therapeutic use; and finally, articles classified as relevant at the third node are tagged as relevant if they do not contain outcomes tagged with metabolism.

A single, simple classifier as above is inadequate for generating accurate predictions. In the example given in Figure 2, it is obvious that automatically discarding articles not tagged as RCTs would exclude relevant articles (such as systematic reviews). However, the GBM algorithm generates a model based on a series of simple classifiers, including, for example, decision trees that discard articles that are not systematic reviews. The algorithm sequentially evaluates each simple model and assigns it a weight computed to minimize the entire model’s overall loss function (in this case based on the logistic function). The final model therefore includes all simple models, but each simple tree is assigned a weight proportional to its accuracy. By taking a weighted average across simple, weak classification trees, it is possible to generate more accurate predictions.

We validated the results on these training data using five-fold cross validation (which reduces overfitting). Each fold of cross validation randomly selects 20 percent of the data to serve as test data; then the process fits a model on the remaining 80 percent of the data; finally, model performance is measured on the reserved test data. The process is repeated on all 5 folds and one ultimately finds the model which would minimize the prediction error averaged across all 5 folds and models. This approach reduces both overfitting (using cross validation) and improves overall performance (using boosting). The output results were probabilities that the articles were relevant; we examined a receiver operator characteristic (ROC) curve to determine the optimal probability threshold for minimizing both false negatives and false positives using only the original search results.

We also used the GLMnet method, which is a parametric approach in that one fits a linear logistic model with convex penalty on the magnitude of coefficients. As above, we model the outcome variable (inclusion in the report for efficacy/effectiveness or AEs) as a function of the explanatory variables described above. In a standard linear model, the outcome would be made a function of all explanatory variables, but this may lead to over-fitting. The Lasso shrinkage and selection method for linear regression (and generalizations such as Elastic-Net) minimizes the usual sum of squared errors, with a bound on the sum of the absolute values of the coefficients.23 The GLMnet method shrinks coefficients of less important variables to zero with a more general convex penalty, resulting in fewer independent variables that have better predictive power. GLMnet also employs cyclical coordinate descent (computed along a regularization path) to efficiently solve these problems.37 Both algorithms (GLMnet and GBM) outputted prediction probabilities that could be judged against the gold standard results obtained by the SCEPC team. Finally, to bridge some of the large differences between the parametric GLMnet and non-parametric GBM procedures, we created a hybrid approach that would reject articles only if both procedures rejected them. Equivalently, we accepted articles if either procedure assigned sufficiently high probability of relevance to them. Of note, we considered using SVM and other established methods such as latent semantic indexing, but we chose GLMnet and GBM based on our prior experience, and because several reports suggested that it would be unlikely that SVM would be markedly superior to GBM and GLMnet.16,38,39

We generated prediction scores for the updated searches (2006–2010 literature for LBD and 2007–2010 for AAP–the test data) using the models and thresholds generated above. We generated a set of predicted relevant and irrelevant articles that we compared against decisions that members of the EPC team generated independently. We then calculated performance: sensitivity (% relevant articles retrieved, also known as recall) and positive predictive value (PPV: % predicted relevant articles that were truly relevant, also known as precision). We also computed the proportion of workload (literature search screening of both relevant and irrelevant articles) that might have been avoided had this predictive model been used exclusively.

We evaluated performance at multiple probability thresholds. There is no perfect threshold, because neither error minimization nor sensitivity maximization can be considered absolute goals; a strategy that rejected all articles might have an error rate of 1 percent (though all would be false negatives) while a strategy accepting all articles would have 100 percent sensitivity (though low PPV). To balance these objectives and conform to researcher preferences, we often judged primary results against a probability threshold of p≥0.02 because this threshold appeared to substantially reduce the error rate while preserving sensitivity. However, we also derived sensitivity-maximizing thresholds based on performance in the original AAP and LBD studies. As described below, these empirically derived thresholds differed between the two studies. We also evaluated the performance of these approaches (GLMnet and GBM) by comparing their Receiver Operating Characteristic (ROC) curves visually and via a non-parametric approach. 40 Of note, pure statistical comparisons may not produce the best results (from the perspective of comparative effectiveness review researchers) because maximizing the area under the curve (AUC) does not automatically select the proper balance of sensitivity and PPV/specificity.

To estimate model variability, we calculated bootstrapped standard errors for the sensitivity and PPV results.41 We generated 100 models by sampling with replacement from the original literature review articles. We then generated 100 sets of predictions by applying each of the models to the actual data (from the original and updated reports); we calculated standard errors from the resulting simulated sensitivity and PPV estimates. However, at the plausible thresholds discussed in the report (0<p<=.1), the standard errors were extremely small (due to the large sample sizes of the training data used to fit the original models) and are not shown for each case. For example, for sensitivity at a threshold of 0.1 for the original LBD study (efficacy), the estimated sensitivity was 0.995 and the standard error was 0.0008.