# Introduction

Clinicians, clinical guideline developers, regulatory agencies, and research granting agencies all use systematic reviews to determine appropriate clinical practice and research needs. As such, systematic reviews need to be updated to maintain their utility; static reviews potentially ignore new research that could change the results of a systematic review, and thus clinical practice, substantially.1,2 Given these concerns, several experts suggested updating systematic reviews every 2 years and perhaps more often for rapidly advancing fields.1,3,4

In actual practice, a minority of systematic reviews are updated that frequently.5,6 Several researchers have explored why updating frequency may fall short of the standard. First, updates may entail substantial cost, as the entire process of literature retrieval, filtering, data extraction, and interpretation needs to be repeated. Researchers filter citations in two labor-intensive stages: the first stage excludes articles that are obviously irrelevant based on reading the title and/or abstract; the second stage excludes additional studies after reading or screening the full text.7–9 In typical comparative effectiveness reviews, researchers retain remaining articles that are useful for analyses of efficacy/effectiveness or AEs (or some other outcome such as utilization). In several AHRQ comparative effectiveness review updates of rapidly advancing fields, researchers needed to screen thousands of citations to locate the 1–10 percent that were relevant;7–11 such efforts matched or exceeded those involved in the original studies. Second, validated updating protocols and algorithms for determining true signals are still under development.12,13 Finally, getting updates published in peer-reviewed journals may be more difficult than getting the original review published.6

As a first step toward automating part of this process, several studies described information retrieval technologies aimed at improving the efficiency of relevant biomedical literature retrieval.14,15 16–22 Several focused specifically on reducing the human burden of systematic review creation and updating by limiting the number of retrieved citations that require initial human review.14,15,17,20 As acknowledged by many of the above studies, systematic review facilitation is complicated by the relative paucity of relevant articles when compared to irrelevant literature; the above studies used a variety of approaches to try to mitigate such issues. These studies typically extracted large numbers of features (explanatory variables) based on variants of a “bag-of-words” approach. In this approach, all terms in the text as well as MeSH indexing terms and publication types were used to create variables based on the presence or frequency of particular terms in the text or MeSH index of each article. Some studies added domain knowledge when classifying features using, for example, United Medical Language System (UMLS).19 A variety of algorithms have been used to model relevance as a function of these many thousands of potential explanatory variables. These include a support vector machines (SVM), a voting perceptron-based classifier, Naïve Bayes, boosting, a specialized AdaBoost algorithm, and linear and polynomial SVM.14–17,19,20

In the specific context of systematic review facilitation, one study used a voting perceptron classifier to identify relevant articles on multiple systematic reviews (and explanatory variables derived from a bag-of-words approach).14 The study reported work reductions for 11 of the 15 topics while maintaining 95 percent sensitivity for relevant articles; for 3 of those 11, the reduction was more than 50 percent. A later related study used a classifier based on the SVMlight algorithm as well as a bag-of-words feature set to predict updates to multiple systematic reviews prospectively (i.e. using earlier studies to predict studies retrieved in later years).21 The investigators found that predictive performance as measured by area under the receiver operating curve (AUC) was stable in the update when compared to predictions generated for training data.

Another research group used an active-learning strategy to aid the creation of new systematic reviews.15,20 Similar to the above study, the model predicts relevance based on independent variables derived from multiple sources including MeSH and text. However, they used a process that interactively builds a classifier using expert decisions on the most uncertain cases; the underlying hypothesis is that decisions chosen on the most uncertain instances produce better information for a given cost (reviewer time). They were able to reduce the number of citations that needed to be screened in a simulated de novo review by roughly 50 percent while retaining 100 percent of relevant articles.

The above studies all employed thousands of explanatory variables. While predictive accuracy is the main goal of machine learning, model parsimony may contribute toward improving out-of-sample predictions.23–25 We hypothesized that a parsimonious approach making explicit use of domain knowledge might be useful in comparative effectiveness review updating, because the original reviews frequently generate thousands of training observations and include substantial domain knowledge. We further hypothesized that the effort MEDLINE researchers put into indexing key concepts with subheadings can be leveraged for substantial predictive power, without requiring significant human reviewer input.

MeSH indexing identifies key concepts in articles, which has proven very useful as a tool for retrieving literature. However, MeSH indexing further describes those concepts with descriptive subheadings (“chemically induced”, “adverse effects”, “epidemiology”, etc.). Extracting data solely on a few key variables related to publication type, intervention, and outcome may have sufficient power, counterbalancing the slightly greater upfront time required for identifying key concepts beforehand. For example, if researchers are interested whether alendronate is safe and effective in preventing fractures, the most crucial variables might be those indicating whether the indexing term for alendronate is tagged with “therapeutic use” and whether the corresponding term for fracture is associated with “prevention and control”. These and other key variables might be imperfect individually but their combination could yield a model that robustly predicts relevance. We published earlier work validating this approach for extracting articles that tested whether particular drugs caused any type of adverse effect (AE) regardless of study design.26 In this study, we adapted our earlier approach to make it useful for locating studies relevant to comparative effectiveness reviews, which require all articles assessing either efficacy/effectiveness or AEs using particular study designs.

We tested the utility of a MeSH-based approach to text classification using two comparative effectiveness reviews. The first concerned the prevention of fractures in patients with osteopenia or osteoporosis (low bone density [LBD]) conducted by the Southern California Evidence-based Practice Center (SCEPC), under contract to the Agency for Healthcare Research and Quality (AHRQ).7,8 EPC researchers conducted the initial comparative effectiveness review in 2006 using literature indexed in multiple sources including PubMed. As it became apparent that the field was advancing rapidly, the EPC group and AHRQ determined that an update was necessary; an updated literature search was conducted in 2010 that searched for new literature (2006–2010) covering the same interventions and conditions, as well as all literature for newly relevant interventions and conditions (discussed below). The second comparative effectiveness review covered off-label indications for atypical anti-psychotic drugs (AAP).9 The first AAP review covered literature published until December 2006, and the update covered literature published subsequent to that date. In each case, we aimed to use the earlier study’s reviewer decisions to create a predictive model that could classify articles in the updated search results as meeting the criteria of second-stage filtering. Such studies were relevant for efficacy/effectiveness analyses, relevant for AE analyses, or irrelevant for both.

The key challenge in using machine learning to facilitate systematic and comparative effectiveness review updates lies in accounting for the differences between the training (original search) and test (updated search) data. In both the LBD and AAP reviews, new conditions and interventions were added and others were dropped. Furthermore, both research personnel and study objectives changed between the first and updated review. In other contexts, the general problem of training data becoming inapplicable to test data over time has been described as “concept drift”.27–31 Researchers have devised several strategies to address this problem including giving weight to more recent training observations or to the small number of classified test observations (if present). An earlier study explored how well an SVM-based machine learning framework performed in light of this issue on a series of systematic reviews, some of whose search criteria were revised significantly.21 They found that their framework performed well in many cases, though they noted that it was uncertain whether reviewers would be satisfied with their prospective performance in all cases and they did not explicitly address changes over time.

In this study, we simulated a true update by creating predictive models while blinded to “true positive” and “true negative” articles from the update, while addressing the fact that both the AAP and LBD reviews substantially revised their inclusion criteria. To address concept drift in this context, we therefore elected to represent specific drugs and outcomes as more abstract concepts such as “intervention” and “outcome”, with the hypothesis that this procedure would improve generalizability between time periods. We hypothesized that reviewers wanted the same types of studies, even though the exact interventions and outcomes differed. In the rest of the manuscript, we describe this method in detail and simulate how such a system might perform in predicting articles that would have passed the second stage screening process and been included in the update report for either AEs or efficacy/effectiveness.